# List of Excluded Studies and Unobtained Studies

Eight hundred and forty-four studies were excluded. The reasons for exclusion are as follows: (1) the study was not primary research (n=153), (2) the study was published before 1990 (n=4), (3) the study enrolled 10 or fewer participants (n=34), (4) no baseline data was provided (n=89), (5) inappropriate study design (n=182), (6) the study population did not meet our criteria (n=15), (7) rotator cuff (RC) tears were not confirmed using diagnostic imaging (n=107), (8) the primary intention of the study was not the treatment of RC tears (n=59), (9) the study intervention did not meet our criteria (n=47), (10) there were no numeric outcome of interest reported (n=39), (11) the followup duration was less than 12 months in operative studies (n=23), (12) the study was not published in English (n=79), (13) the article was a multiple publication of an included study (n=13). In addition, 29 studies could not be retrieved through the univeristy interlibrary loan service.

## Excluded – Not Primary Research (N = 153)

The following studies were excluded because they were not primary research.

1 Ahmad CS, Levine W. Arthroscopic rotator cuff repair. Orthopedics. 2004;27(6):570-574. [pmid: 15237896].
2 Altchek D. Arthroscopy of the shoulder. Scand J Med Sci Sports. 1995;5(2):71-75. [pmid: 7606513].
3 Anderl W. Neuentwicklungen in der orthopadischchirurgischen therapie der schulter: schulterdiagnostik. Radiologe. 2004;44(6):613-619. (Fre). [pmid: 15156285].
4 Andrews JR. Diagnosis and treatment of chronic painful shoulder: review of nonsurgical interventions. Arthroscopy. 2005;21(3):333-347. [pmid: 15756189].
5 Augereau B. [Surgical treatment of rotator cuff ruptures. Shoulder surgery in the adult: A collection of SOFCOT lectures]. 1993:137-154. (Fre).
6 Augereau B. Indications therapeutiques [Full-thickness tears of the rotator cuff, including subscapularis: conclusions and therapeutic indications]. Rev Chir Orthop Reparatrice Appar Mot. 1999;85:136-138. (Fre). [pmid: 10392414].
7 Augustine SJ, McCluskey GM. Mini-open rotator cuff repair. Sports Med Arthrosc. Jul. 2000;8(3):229-238.
8 Azorin M, Cordesse G. Reeducation des ruptures des muscles de la coiffe operees. Kinesither Sci. 1993:34-40. (Fre).
9 Banner I, Peyre M. Place du traitement medicamenteux et des infiltrations dans la prise en charge medicale des lesions de la coiffe des rotateurs. J Traumatol Sport. 2007;24(2):93-98. (Fre).
10 Bauer C, Gesslein M. Rotatorenmanschetten-Ruptur [Rupture of the rotator cuff]. MMW Fortschr Med. Feb. 7. 150. 2008;(6):41. (Ger).
11 Bauer GJ, Kniesel B. Arthroscopic reconstruction of the rotor cuff. Unfallchirurg. 2006;109(8):619-627. [pmid: 16897022].
12 Beaudreuil J, Revel M. Physiopathologie et reeducation des lesions de la coiffe des rotateurs. Actual Rheumatol. 1998:422-435.
13 Bigliani LU. Die beziehung von akromialarchitektur zu erkrankungen der rotatorenmanschette. Orthopade. 1991;20(5):302-309. (Ger). [pmid: 1745540].
14 Bleton R. Les ruptures des tendons des muscles de la coiffe des rotateurs de l’ epaule. Kinesither Sci. 1993:27-33. (Fre).
15 Blevins FT, Warren RF. Diagnostic arthroscopy and arthroscopic management of rotator cuff tears Master Techniques in Orthopaedic Surgery. The Shoulder New York. New York. Raven Press. 1995:399-416.
16 Blevins FT. Rotator cuff pathology in athletes. Sports Med. 1997;24(3):205-220. [pmid: 9327536].
17 Bøhmer AS, Staff PH, Brox JI. Supervised exercises in relation to rotator cuff disease (impingement syndrome stages II and III): a treatment regimen and its rationale. Physiother Theory Pract. 1998;14(2):93-105.
18 Bohsali KI. Current concepts review: complications of total shoulder arthroplasty. J Bone Joint Surg Am. 2006;88(10):2279-2292. [pmid: 17015609].
19 Bover T, Frank A. Societe francaise de rhumatologie Fp. L’ arthroscopie dans la pathologie de la coiffe des rotateurs de l’ epaule. Seizieme journee de Bichat «Appareil locomoteur» - 29 mars 2003. Seance pleniere (1ere partie). Rhumatologie. 2003;55(2):22-30. (Fre).
20 Breazeale N, Craig E. Partial-thickness rotator cuff tears: pathogenesis and treatment. The rotator cuff, Part II. Orthop Clin North Am. 1997;28(2):145-155. [pmid: 9113711].
21 Brems JJ. Repair of massive rotator cuff tears: method of mobilization and tissue coverage. Craig EV, editor. The Shoulder. New York. Raven Press. 1995:35-54.
22 Brewster C, Moynes DR. Rehabilitation of the shoulder following rotator cuff injury or surgery. J Orthop Sports Phys Ther. 1993;18(2):422-426. [pmid: 8364597].
23 Brislin K, Rubenstein D, Wetzler M, et al. Operative repair of anterior instability and rotator cuff tears in athletes. Oper Tech Sports Med. Apr. 2002;10(2):64-68.
24 Browning DG, Desai MM. Rotator cuff injuries and treatment. Prim Care. 2004;31(4):807. [pmid: 15544822].
25 Buchbinder R, Green S, Youd JM. Corticosteroid injections for shoulder pain. Cochrane Database Syst Rev CD004016. 2003;(1).
26 Buckley P, Grana WA. How to treat rotator cuff injuries. Phys Sportsmed. May. 1993;21(5):144t.
27 Budoff JE. The etiology of rotator cuff disease and treatment of partial-thickness pathology. J Hand Surg Am. 2005;5(3):139-152.
28 Burkhart SS. Arthroscopic treatment of massive rotator cuff tears. Clin Orthop Relat Res. 2001:107-118.
29 Burkhart SS, Klein JR. Arthroscopic treatment of full-thickness rotator cuff tears in the athlete. Oper Tech Sports Med. Apr. 2004;12(2):122-125.
30 Burns JP, Snyder SJ, Albritton M. Arthroscopic rotator cuff repair using triple-loaded anchors, suture shuttles, and suture savers. J Am Acad Orthop Surg. 2007;15(7):432-444. [pmid: 17602032].
31 Centre for Reviews and Dissemination. Arthroscopic versus open acromioplasty: a systematic review [structured abstract]. 2008.
32 Checroun AJ, Dennis MG, Zuckerman JD. Open versus arthroscopic decompression for subacromial impingement: a comprehensive review of the literature from the last 25 years. [Review] [41 refs]. Bull Hosp Joint Dis. 1998;57(3):145-151.
33 Christel P, Parier J, Djian P, et al. Les ruptures isolees du tendon du muscle sous scapulaire chez le sportif [Isolated lesion of subscapularis]. Rhumatologie. 1992;44(9/10):225-228. (Fre).
34 Codman EA. Rupture of the supraspinatus tendon. Clin Orthop Relat Res. 1990:3-26.
35 Coiffe des rotateurs et masso-kinesitherapie. Kinesither Sci. 2002:28-31. (Fre).
36 Colne P. Bilan kinesitherapique des lesions de la coiffe des rotateurs: quelques aspects particuliers de la prise en charge kinesitherapique a travers une analyse de la litterature recente [Physical therapy for rotator cuff tears: specific management techniques reported in the literature]. Kinesitherapie. Nov. 2001:34-37. (Fre).
37 Colne P. Mobilisations de l’ epaule et techniques de renforcement. Kinesitherapie. 2002:35-37. (Fre).
38 Conway JE, Romeo A. Arthroscopic repair of partial-thickness rotator cuff tears and slap lesions in professional baseball players: repair of athletic shoulder Injuries. Orthop Clin North Am. 443-viii. 2001;32(3):viii-456.
39 Cordasco FA, Bigliani LU. Large and massive tears: technique of open repair. The rotator cuff, Part II. Orthop Clin North Am. 1997;28(2):179-193. [pmid: 9113714].
40 Craig EV. Open anterior acromioplasty for full-thickness rotator cuff tears. Master techniques in orthopaedic surgery: The shoulder. 1995:3-33.
41 Cross T, Crichton K. Rotator cuff problems in sport. Med Today. 2006;7(11):75-79.
42 Dalton SE. The conservative management of rotator cuff disorders. Br J Rheumatol. 1994;33(7):663-667. [pmid: 8019796].
43 Darnault A, Heuleu J, Daniel F, et al. Les lésions dégénératives de la coiffe: stratégies thérapeutiques. [Therapeutic strategies for degenerative rotator cuff lesions]. Rhumatologie. 2001;53(4):17-19. (Fre).
44 Darnault A, Heuleu J. Les lesions degeneratives de la coiffe: strategies therapeutiques. Rhumatologie. 2001;53(4):17-19. (Fre).
45 De Lecluse J, Peyre M. Societe francaise de rhumatologie Fp. Les tendinopathies non rompues de la coiffe: place de la reeducation. Seizieme journee de Bichat «Appareil locomoteur» - 29 mars 2003. Seance pleniere (1ere partie). Rhumatologie. 2003;55(2):15-19. (Fre).
46 Dermid JC, Holtby R. All-arthroscopic versus mini-open repair of small or moderate-sized rotator cuff tears: a protocol for a randomized trial [NCT00128076]. BMC Musculoskelet Disord. 2006;7(25):25. [pmid: 16529658].
47 Dietz SO, Habermeyer P, Magosch P. Current concepts in treatment of rotator cuff tears. Zentralbl Chir. 2002;127(3):194-202. [pmid: 11935482].
48 Digiovanni J, Marra G. Hemiarthroplasty for glenohumeral arthritis with massive rotator cuff tears: total shoulder arthroplasty. Orthop Clin North Am. 1998;29(3):477-489. ix. [pmid: 9706294].
49 Dines DM, Moynihan DP, Dines JS, et al. Irreparable rotator cuff tears: what to do and when to do it; The surgeon’s dilemma. J Bone Joint Surg Am. 2006;88(10):2294-2302. [pmid: 17066569].
50 Douoguih WA, Shaffer BS. Avoiding complications in arthroscopic subacromial space and instability surgery. Oper Tech Sports Med. 2004;12(2):91-98.
51 Dumontier C, Roukoz S. Tendinites et petites ruptures des muscles de la coiffe: traitement chirurgical. Cah Kinésithér. 1993;162(4):29-35. (Fre).
52 Ehrler S, Chapron J. Place de l’ ergotherapie dans la reeducation et la readaptation apres lesion de la coiffe des rotateurs. Journal d’ergotherapie. 1993;15(1):26-27. (Fre).
53 Esch JC. Arthroscopic subacromial decompression and postoperative management. Orthop Clin North Am. 1993;24(1):161-171. [pmid: 8421609].
54 Favard L, Bacle G, Berhouet J, et al. La chirurgie reparatrice de la coiffe des rotateurs. 20e Congres francais de rhumatologie. Paris. 2–5, decembre 2007. Rev Rhum Ed Fr. 2007;74:10-11. 954. 960. (Fre).
55 Favard L, Bacle G, Berhouet J. Rotator cuff repair. Joint Bone Spine. 2007;74(6):551-557. [pmid: 17993287].
56 Fichez O. Pathologie de la coiffe des rotateurs et conflit sous-acromial de l’ epaule du lanceur. J Traumatol Sport. 1999;16(4):240-243.
57 Finnish Office for Healthcare Technology Assessment (FinOHTA). Shoulder impingement syndrome (project) (brief record). 2008.
58 Flurin PH, Guillo S. Reparation arthroscopique des ruptures transfixiantes de la coiffe: chirurgie arthroscopique du membre superieur. Chir Main. 2006;25:S60-69. (Fre). [pmid: 17361873].
59 Fongemie AE, Buss DD, Rolnick SJ. Management of shoulder impingement syndrome and rotator cuff tears. Am Fam Physician. 1998;57(4):667-674. [pmid: 9490991].
60 Fouse M, Nottage WM. All-arthroscopic rotator cuff repair. Sports Med Arthrosc. 2007;15(4):208-215. [pmid: 18004220].
61 Gachter A. Stellenwert der arthroskopie in der diagnose und therapie von schultergelenksverletzungen [Value of arthroscopy in the diagnosis and therapy of shoulder joint injuries]. Der Chirurg. 1993;64(3):157-162. (Ger).
62 Gartsman GM. Arthroscopic rotator cuff repair. Clinical orthopaedics and related research. 2001;390:95-106. [pmid: 11550881].
63 Gartsman GM. Combined arthroscopic and open treatment of tears of the rotator cuff. J Bone Joint Surg Am. 1997;79(5):776-783.
64 Gartsman GM, Hammerman SM. Full-thickness tears: arthroscopic repair. Orthop Clin North Am. 1997;28(1):83-98. [pmid: 9024434].
65 Gartsman GM. Rotator cuff repair: why I prefer arthroscopy. Sports Med Arthrosc. Apr. 1999;7(2):85-92.
66 Gazielly D. Les ruptures transfixiantes de la coiffe des rotateurs: caractéristiques d’une bonne réparation à ciel ouvert [Full-thickness tears of the rotator cuff, including subscapularis: characteristics of open surgical repair]. Rev Chir Orthop Reparatrice Appar Mot. 1999;85.
67 Gazielly DF. Rupture de la coiffe des rotateurs de l’ epaule. Cahiers d’enseignement de la SOFCOT. 1997;62:165-185. (Fre).
68 Gerber C. Epaule: la reinsertion de la coiffe quelques details techniques. Ann Orthop Ouest. 2001:25-26. (Fre).
69 Gohlke F, Rolf O, Bohm D. Open reconstruction of the rotator cuff. Orthopade. 2007;36(9):834. [pmid: 17687540].
70 Gortner U. Schmerzbehandlung. mit. komplexer reflexzonentherapie mach jost thomas am beispiel von insertionstendopathien oder artropathien an der schulter. Krankengymnastik. 1999;51(7).
71 Goutallier D, Postel J. Traitement chirurgical des larges ruptures de la coiffe des rotateurs. Actual Rheumatol. 1994:398-407.
72 Goutallier D, Postel JM. Faut-il reparer les ruptures de la coiffe de l’ epaule. Actual Rheumatol. 2002:438-449.
73 Goutallier D, Postel JM. A propos de l’ article “Etude par arthroscanner de la cicatrisation tendineuse apres reparation arthroscopique de la coiffe des rotateurs: analyse des facteurs predictifs a propos d’ une serie consecutive de 167 reparations”. Rev Chir Orthop Reparatrice Appar Mot. 2007;93(8):863-864. (Fre). [pmid: 18166961].
74 Green S, Buchbinder R, Hetrick S. Acupuncture for shoulder pain. [Review] [40 refs]. Cochrane Database Syst Rev CD005319. 2005;(2).
75 Gudmestad J. Arm yourself against injury: a torn rotator cuff can mean searing pain, slow healing, and even surgery. But yoga can strengthen your shoulders and help prevent problems. Yoga J. Dec. 2003;(178):129-131.
76 Gupta R, Leggin BG, Iannotti JP. Results of surgical repair of full-thickness tears of the rotator cuff. Orthop Clin North Am. Apr. 1997;28(2):241-248. [pmid: 9113719].
77 Haas M. Verletzungen im bereich des schultergelenks und ihre krankengymnastiche behandlung. Krankengymnastik. 1992;44(9):1106-1124. (Ger).
78 Handelberg FWJ. Societe francaise de chirurgie orthopedique et traumatologique. Protheses d’ epaule et rupture de coiffe. Conferences d’ enseignement 2002. Cahiers d’enseignement de la SOFCOT. 2002;79:21-31. (Fre).
79 Hardy P. Indication de l’ arthroscopie dans les lesions de la coiffe des rotateurs. XVIIe Journees de reeducation de la main et du membre superieur. Paris. 18–19, janvier 2002. Kinesither Sci. 2001:43-45. (Fre).
80 Hardy P. Societe francaise de rhumatologie Fp. Tendinopathie non rompue de la coiffe des rotateurs. Seizieme journee de Bichat “Appareil locomoteur”. 29 mars 2003. Seance pleniere (1ere partie). Rhumatologie. 2003;55(2):20-21. (Fre).
81 Haye M. Institut national de la kinesitherapie PFo. Proposition therapeutique. Confrontations en kinesitherapie. Paris. 6–7, octobre 2006. Kinesither Sci. 2006:25-26. (Fre).
82 Jensen KL, Williams GR Jr, Russell IJ, et al. Rotator cuff tear arthropathy. J Bone Joint Surg Am. Sep. 1999;81(9):1312-1324. [pmid: 10505528].
83 Jokiranta J, Vastamaki M. Massive rotator cuff tears. Ann Chir Gynaecol. 1996;85(2):128-131. [pmid: 8817049].
84 Joncour V, Jully J. Coussin d’ abduction et ajustement postural apres refection de coiffe. Kinesither Sci. 1991;302:15-18. (Fre).
85 Karas EH, Iannotti JP. Failed repair of the rotator cuff: evaluation and treatment of complications. J Bone Joint Surg Am. 1997;79(5):784-793.
86 Kasten P, Loew M. How to treat massive rotator cuff tears. Orthopade. 2007;36(9):855-861. [pmid: 17704906].
87 Kempf JF, Bonnomet F. Place tu traitement chirurgical dans la pathologie de la coiffe des rotateurs. J Med Strasb. 1995;26:1-2. 15. 19. (Fre).
88 Kerkour K, Meier JL, Mansuy J. Reeducation apres lesion degenerative de la coiffe des rotateurs. Schweiz Z Sportmed Sporttraumatol. 2000;48(1):28-36. (Fre).
89 Kozak TK, Cofield RH. Surgery for rotator cuff tears. Morrey BF, editor. Reconstructive surgery of the joints. 2nd ed. New York. Churchill Livingstone Inc. 1996;1 and 2:835-849.
90 Krabak BJ, Sugar R, McFarland EG. Practical nonoperative management of rotator cuff injuries. Clin J Sport Med. 2003;13(2):102-105. [pmid: 12629428].
91 Lafosse L, Brzoska R, Toussaint B, et al. The outcome and structural integrity of arthroscopic rotator cuff repair with use of the double-row suture anchor technique. J Bone Joint Surg Am. 2008;90(Suppl 10):275-286. [pmid: 18829940].
92 Lampert C, Gaechter A. Arthroskopie von schulter und ellbogen [Arthroscopy of shoulder and elbow Basel Contributions to Surgery; Models for interdisciplinary management: 25th anniversary of the Department of Surgery in Basel]. 1993:90-95. (Ger).
93 Le Corroller T, Cohen M. L’ intervalle des rotateurs: des lesions cachees. J Radiol. 2007;88(11):1669-1677. (Fre). [pmid: 18065926].
94 Liebenson C. Self-management of shoulder disorders - Part 3: Treatment. J Bodyw Mov Ther. Jan. 2006;10(1):65-70.
95 Lilleby H. Indikationen zur operativen schulterarthroskopie [Indications for surgical shoulder arthroscopy]. Hempfling H, editor. Arthroskopie. Indikation, Bedeutung, Begutachtung. Stuttgart, Germany. Gustav Fischer Verlag. 1990:143-144. (Ger).
96 Lohr JF, Uhthoff HK. Epidemiologie und pathophysiologie der rotatorenmanschettenruptures [Epidemiology and pathophysiology of rotator cuff tears]. Orthopade. 2007;36(9).
97 Ludolph E, Schroter F, Besig K. Die begutachtung der rotatorenmanschettenveranderung. Aktuelle Traumatol. 1997;27(1):31-34. (Ger).
98 Ludolph E. Der rotatorenmanschettenschaden: gutachtliche gesichtspunkte. Aktuelle Traumatol. 1992;22(2):82-83. (Ger). [pmid: 1351348].
99 Meister K, Andrews JR. Classification and treatment of rotator cuff injuries in the overhand athlete. J Orthop Sports Phys Ther. 1993;18(2):413-421. [pmid: 8364596].
100 Mestdagh H, Urvoy P. A surgical approach for the repair of large tears of the rotator cuff. Acta Orthop Belg. 1992;58(3):359-361. [pmid: 1441979].
101 Millstein ES, Snyder SJ. Arthroscopic management of partial, full-thickness, and complex rotator cuff tears: Indications, techniques, and complications. Arthroscopy. 2003;19(10):189-199. [pmid: 14673438].
102 Mole D, Sirveaux F. Traitements, résultants fonctionnel et anatomique de la série [Full-thickness tears of the rotator cuff, including subscapularis: principles of surgical technique]. Rev Chir Orthop Reparatrice Appar Mot. 1999;85:100-104. (Fre).
103 Monet J, Dauzac C. Principes de reeducation apres reparation chirurgicale des lesions degeneratives de la coiffe (lambeau deltoidien). Cah Kinésithér. 1993;162(4):66-72. (Fre).
104 National Coordinating Centre for Health Technology Assessment (NCCHTA). The clinical and cost-effectiveness of surgical (arthroscopic or open) versus rest then exercise management for tears of the rotator cuff (UKUFF trial), HTA ref 05/47/02, primary research (project) (brief record). 2008. ST.
105 Neviaser RJF. Evaluation and management of failed rotator cuff repairs. The rotator cuff, Part II. Orthop Clin North Am. 1997;28(2):215-224. [pmid: 9113717].
106 Nho SJ, Shindle M. American Academy of Orthopaedic Surgeons RIUSS. Systematic review of arthroscopic rotator cuff repair and mini-open rotator cuff repair. Selected scientific exhibits: the annual meeting of the American Academy of Orthopaedic Surgeons. San Diego, CA. February 14–18, 2007. J Bone Joint Surg Am. 2007;89(Suppl 3):127-136.
107 Noel E. Evolution naturelle des lesions de la coiffe des rotateurs. Lyon Mediterr Med Med Sud Est. 1997;33:6-7. 2390. 2393. (Fre).
108 Noel E. Les ruptures de la coiffe des rotateurs. Concours medical Paris. 2005;127(15):823-827. (Fre).
109 Nottage WM. Rotator cuff repair with or without acromioplasty. Arthroscopy. 2003;19(10 Suppl 1):229-232. [pmid: 14673443].
110 Nove-Josserand L. Arthroscopie de l’ epaule. Rupture partielle de la coiffe des rotateurs: chirurgie arthroscopique du membre superieur. Chir Main. 2006;25:S50-59. (Fre). [pmid: 17361872].
111 Ozbaydar M, Chung S, Diller D, et al. Arthroscopic reconstruction of the rotator cuff. Orthopade. 2007;36(9):825. [pmid: 17701159].
112 Paulos LE, Franklin JL, Beck CL Jr. Arthroscopic management of rotator cuff tears. Mcginty JB, editor. Operative Arthroscopy. New York. Raven Press. 1991:529-542.
113 Pearce C, Ricketts D, Wall S, et al. Open repair of massive rotator cuff tears in patients aged sixty-five years or over: is it worthwhile? [comment]. J Shoulder Elbow Surg. 2005;14(6):657. [pmid: 16337539].
114 Peterson CA, Altchek DW. Arthroscopic treatment of rotator cuff disorders. Clin Sports Med. Oct. 1996;15(4):715-736. [pmid: 8891404].
115 Piasecki DP, Nicholson GP. Tears of the subscapularis tendon in athletes-diagnosis and repair techniques. Clin Sports Med. 2008;27(4):731. [pmid: 19064153].
116 Pisan M, Gerber C. Clinical examination of the rotator cuff. Curr Orthop. 2000;14(3):155-160.
117 Pocholle M. Reeducation apres reparation de la coiffe des rotateurs de l’ epaule. Ann Kinésithér. 1997;24(8):353-361. (Fre).
118 Pollock RGF. Full-thickness tears: mini-open repair. The rotator cuff, Part II. Orthop Clin North Am. 1997;28(2):169-177. [pmid: 9113713].
119 Povacz P, Resch H. Die rotatorenmanschettenruptur [Rupture of the rotator cuff]. Wien Med Wochenschr. 1996;146:6-7. 135. 138. (Ger).
120 Reardon DJ, Maffulli N. Clinical evidence shows no difference between single- and double-row repair for rotator cuff tears. Arthroscopy. 2007;23(6):670-673. [pmid: 17560483].
121 Reilly P, Emery R. Full thickness rotator cuff tears. Curr Orthop. 2000;14(3):173-181.
122 Resch H. Primar schliessbare rotatorenmanschettenrupturen. Aktuelle Traumatol. 1999;29(1):A1-6. (Ger).
123 Richards DP, Burkhart SS. Subscapularis tears: arthroscopic repair techniques: advanced shouler arthroscopy. Orthop Clin North Am. 2003;34(4):485-498. [pmid: 14984188].
124 Rockwood CAW. Protheses d’ epaule et deficience de la coiffe des rotateurs: protheses d’ epaule. Cahiers d’enseignement de la SOFCOT. 1999;68:219-225. (Fre).
125 Rodriguez-Pinero Duran M, Rodriguez-Burgos C, Cardenas-Clemente J, et al. Arthroplasty of the shoulder. Rehabil. 2007;41(6):248-257.
126 Rudzki JR, Shaffer B. New approaches to diagnosis and arthroscopic management of partial-thickness cuff tears. Clin Sports Med. 2008;27(4):691. [pmid: 19064151].
127 Ruotolo C, Nottage WM. Surgical and nonsurgical management of rotator cuff tears. Arthroscopy. 2002;18(5):527-531. [pmid: 11987065].
128 Ruotolo C, Nottage WM, Flatow EL, et al. Controversial topics in shoulder arthroscopy. Arthroscopy. Feb. 2002;18(2 Suppl 1):65-75. [pmid: 11828347].
129 Ryu RK, Burkhart SS, Parten PM, et al. Complex topics in arthroscopic subacromial space and rotator cuff surgery. Arthroscopy. 2002;18(2 Suppl 1):51-64. [pmid: 11828346].
130 Scheib JS. Diagnosis and rehabilitation of the shoulder impingement syndrome in the overhand and throwing athlete. Rheum Dis Clin North Am. 1990;16(4):971-988. [pmid: 2087587].
131 Schoene ML. New questions about rotator cuff surgery: should acromioplasty always accompany rotator cuff repair?. Sports Med Dig. May. 2000;22(5):49-56.
132 Sklaar J. Test to predict treatment outcome: determining the potential success of conservative treatment of rotator cuff imoingement. S Afr J Physiother. 1995;51(1):13.
133 Speed CA. Fortnightly review: corticosteroid injections in tendon lesions. Br Med J. 2001;323(7309):382-386. [pmid: 11509432].
134 Sperner G, Resch H, Golser K. Klinisches management bei läison der rotatorenmanschette [Clinical management in lesions of the rotator cuff]. Unfallchirurg. 1990;93(7):309-314. (Ger). [pmid: 2200127].
135 Stetson WB, Ryu RKN. Evaluation and arthroscopic treatment of partial rotator cuff tears. Sports Med Arthrosc. 2004;12(2):114-126.
136 Stetson WB, Ryu RKN, Bittar ES. Arthroscopic treatment of partial rotator cuff tears. Oper Tech Sports Med. 2004;12(2):135-148.
137 Sudkamp NP. Die rotatorenmanschettenruptur [Rotator cuff rupture]. Zentralbl Chir. Mar. 2001;126(3):177-183. (Ger). [pmid: 11301882].
138 Terrade P, Gallois D. Ruptures de coiffes operees: implications pratiques en reeducation. Surgical treatment of rotator cuff tears: practical implications for rehabilitation. Sports Med. Apr. 2006;(181):25-26.
139 Terrade P, Gallois D. Ruptures de coiffes operees: implications pratiques en reeducation. Surgical treatment of rotator cuff tears: practical implications for rehabilitation. Sports Med. May. 2006;(182):15-16.
140 Thelen P. Societe francaise de rhumatologie Fp. Les calcifications rebelles de la coiffe : ponction-aspiration-infiltration. Seizieme journee de Bichat “Appareil locomoteur” - 29 mars 2003. Seance pleniere (1ere partie). Rhumatologie. 2003;55(2):12-14.
141 Thierry M. Criteres de suivi en reeducation et d’orientation en ambulatoire ou en SSR apres chirurgie des ruptures de coiffe ou arthroplasties d’epaule: Syntheses des recommandations professionnelles. La reeducation de l’ epaule prend son envol. Kinesitherapie scientifique. 2008;489:27-29.
142 Thomazeau H. Shoulder arthroscopy and rotator cuff tears repair. Rev Chir Orthop Reparatrice Appar Mot. 2008;94(8 Suppl):394-397. [pmid: 19046698].
143 Tonino PM, Gerber C, Itoi E, et al. Complex shoulder disorders: evaluation and treatment. J Am Acad Orthop Surg. 2009;17(3):125-136. [pmid: 19264706].
144 Travis RD, Burkhead WZ. Technique for repair of the subscapularis tendon: repair of athletic Shoulder Injuries. Orthop Clin North Am. 2001;32(3):495-500. [pmid: 11888144].
145 Trojian T, Stevenson JH, Agrawal N. What can we expect from nonoperative treatment options for shoulder pain?. J Fam Pract. 2005;54(3):216-223. [pmid: 15755374].
146 Walch G, Riand N. Ruptures aigues de la coiffe des rotateurs: traumatismes recents de l’ epaule. Cahiers d’enseignement de la SOFCOT. 1996;56:255-260. (Fre).
147 Walch G, Calderone S. Les lesions de la coiffe des rotateurs liees au sport. Rev Chir Orthop Reparatrice Appar Mot. 1998;84.
148 Warner JJP, Warren RF. Consideration and management of rotator cuff tears in athletes. Ann Chir Gynaecol. 1991;80(2):160-167. [pmid: 1897883].
149 Warner JJP. The treatment of stiffness of the shoulder after repair of the rotator cuff. J Bone Joint Surg Am. 1997;79(8):1260-1269.
150 Wolff AB, Magit DP, Miller SR, et al. Arthroscopic fixation of bursal-sided rotator cuff tears. Arthroscopy. 2006;22(11):1247.e1. [pmid: 17084305].
151 Yamaguchi K, Flatow EL. Arthroscopic evaluation and treatment of the rotator cuff: arthroscopy of the upper extremity. Orthop Clin North Am. 1995;26(4):643-659. [pmid: 7566910].
152 Yamaguchi K. Mini-open rotator cuff repair: an updated perspective. J Bone Joint Surg Am. 2001;83(5):764-772.
153 Zhao H, Wu HS. Evolution of arthroscopy: from a technique to a subspecialty. Chin Med J. 2008;121(15):1462-1468. [pmid: 18959127].

## Excluded – Published Before 1990 (N = 4)

The following studies were excluded because they were published before 1990.

1 Biedert R, Kentsch A. [Arthroscopic subacromial decompression in chronic impingement syndrome]. Unfallchirurg. 1989;92(10):500-504. (Ger). [pmid: 2814523].
2 Neer CS. Anterior acromioplasty for the chronic impingement syndrome in the shoulder: a preliminary report. J Bone Joint Surg Am. 1972;54(1):41-50. [pmid: 5054450].
3 Saragaglia D, Bellon P, Plawecki S, et al. [The impingement syndrome 50 cases operated on by Neer’s anterior acromioplasty]. Rhumatologie. 1989;41(8):235-239. (Fre).
4 Takagishi N. Conservative treatment of the ruptures of the rotator cuff. Orthopaedic Survey. 1978;2(3):186-187.

## Excluded – Enrolled ≤10 Participants (N = 34)

The following studies were excluded because 10 or fewer participants were enrolled.

1 Abrahams S. Acupuncture treatment for a rotator cuff tear, and avoidance of surgery. AACP Journal. 2005:38-42.
2 Ainsworth R. Physiotherapy rehabilitation in patients with massive, irreparable rotator cuff tears. Musculoskeletal Care. Sep. 2006;4(3):140-151. [pmid: 17042025].
3 Auethavekiat P, Michet J. Rotator-cuff tear. New Egypt J Med. 2006;354(19):e20.
4 Badhe SP, Lawrence TM, Smith FD, et al. An assessment of porcine dermal xenograft as an augmentation graft in the treatment of extensive rotator cuff tears. J Shoulder Elbow Surg. Jan. 2008;17(1 Suppl 35):35S-39S. [pmid: 18201655].
5 Beauchamp M, Roy JD. Arthroscopic repair of large and massive rotator cuff tears performed under local anaesthesia and sedation. J Shoulder Elbow Surg. 2009;18(5):e18-e20. [pmid: 19286399].
6 Bennett WF. Arthroscopic repair of isolated subscapularis tears: a prospective cohort with 2- to 4-year follow-up. Arthroscopy. Feb. 2003;19(2):131-143. [pmid: 12579145].
7 Boyles RE, Flynn TW, Whitman JM. Manipulation following regional interscalene anesthetic block for shoulder adhesive capsulitis: a case series. Man Ther. 2005;10(1):80-87. [pmid: 15681274].
8 Deberardino TM, Owens BD. All-inside arthroscopic repair of partial-thickness supraspinatus tendon tear. Tech Shoulder Elbow Surg. 2007;8(3):117-119.
9 Harryman DT. Management of stiffness after rotator cuff tears and repairs. Sports Med Arthrosc. Jul. 1999;7(3):174-187.
10 Hartsell HD. Postsurgical shoulder strength in the older patient. J Orthop Sports Phys Ther. Dec. 1993;18(6):667-672. [pmid: 8281180].
11 Hepp P, Engel T, Osterhoff G, et al. Knotless anatomic double-layer double-row rotator cuff repair: a novel technique re-establishing footprint and shape of full-thickness tears. Arch Orthop Trauma Surg. 2009;129(8):1031-1036. [pmid: 18392596].
12 Herrera MF, Bauer G, Reynolds F, et al. Infection after mini-open rotator cuff repair. J Shoulder Elbow Surg. Nov. 2002;11(6):605-608. [pmid: 12469087].
13 Hoellrich RG, Gasser SI, Morrison DS, et al. Electromyographic evaluation after primary repair of massive rotator cuff tears. J Shoulder Elbow Surg. May. 2005;14(3):269-272. [pmid: 15889025].
14 Holmes TT, Buzzell JE, Dunn WR, et al. Intra-articular pain pump catheter breakage after arthroscopic shoulder surgery: a case series. J Shoulder Elbow Surg. 2007;16(6):e6-e9. [pmid: 17507242].
15 Itoi E, Tabata S. Rotator cuff tears in the adolescent. Orthopedics. 1993;16(1):78-81. [pmid: 8421663].
16 Jully JL, Scheffer JC, Katz D. Place du traitement fonctionnel dans les ruptures de coiffe des rotateurs. J Réadapt Méd. 1991;11(4):227-230. (Fre).
17 Kilinc AS, Ebrahimzadeh MH, Lafosse L. Subacromial internal spacer for rotator cuff tendon repair: “the balloon technique. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2009;25(8):921-924.
18 Kim KC, Rhee KJ, Shin HD, et al. Arthroscopic footprint reconstruction of bursal-side delaminated rotator cuff tears using the suture-bridge technique. Knee Surg Sports Traumatol Arthrosc. 2009;17(7):840-843. [pmid: 19225759].
19 Kirkley A, Griffin S, McLintock H, et al. The development and evaluation of a disease-specific quality of life measurement tool for shoulder instability. The Western Ontario Shoulder Instability Index (WOSI). Am J Sports Med. 1998;26(6):764-772. [pmid: 9850776].
20 Leonhardt G, Ferbert A. Atemsynchrone muskelaktivitat in proximalen arm-und schultermuskeln nach traumatischer plexus und wurzellasion. Nervenarzt. 1991;62(4):252-255. (Ger). [pmid: 1857460].
21 Lo IKY, Burkhart SS. Arthroscopic repair of massive, contracted, immobile rotator cuff tears using single and double interval slides: technique and preliminary results. Arthroscopy. Jan. 2004;20(1):22-33. [pmid: 14716275].
22 Matsen FA III. Clinical practice. Rotator-cuff failure. N Engl J Med. 2008;358(20):2138-2147. [pmid: 18480206].
23 McCreesh K. Evidence based prognosis setting in the case of a conservatively managed rotator cuff tear. Physiother Irel. 2007;28(1):31-35.
24 Melillo AS, Savoie FH III, Field LD. Massive rotator cuff tears: debridement versus repair. Orthop Clin North Am. Jan. 1997;28(1):117-124. [pmid: 9024436].
25 Nord KD, Gothelf T. Rotator Cuff Repair Utilizing the Anterolateral Portal: The 3D Repair. 24th Annual Meeting of the Mid-America Orthopaedic Association. San Antonio, Texas. April 19–23, 2006.
26 Norwood LA, Fowler HL. Rotator cuff tears a shoulder arthroscopy complication. Am J Sports Med. 1989;17(6):837-841. [pmid: 2624296].
27 Oh JH, Kim SH, Lee HK, et al. Trans-rotator cuff portal is safe for arthroscopic superior labral anterior and posterior lesion repair: clinical and radiological analysis of 58 SLAP lesions. Am J Sports Med. 2008;36(10):1913-1921. [pmid: 18495968].
28 Ostrander RV III, Andrews J. Arthroscopic triple-row rotator cuff repair: a modified suture-bridge technique. Orthopedics. 2009;32(8):566. [pmid: 19681543].
29 Richards AM, Curtis MJ. Fracture of an os acromiale with associated rupture of the coracoclavicular ligaments. J Shoulder Elbow Surg. 2008;17(6):e8-e11. [pmid: 18595742].
30 Richman N, Curtis A, Hayman M. Acromion-splitting approach through an os acromiale for repair of a massive rotator cuff tear. Arthroscopy. Oct. 1997;13(5):652-655. [pmid: 9343659].
31 Soyer J, Vaz S, Pries P, et al. The relationship between clinical outcomes and the amount of arthroscopic acromial resection. Arthroscopy. Jan. 2003;19(1):34-39. [pmid: 12522400].
32 Steenbrink F, de Groot JH, Veeger HE, et al. Pathological muscle activation patterns in patients with massive rotator cuff tears, with and without subacromial anaesthetics. Man Ther. Aug. 2006;11(3):231-237. [pmid: 16890886].
33 Sundberg G. [Patients’ experiences of the rehabilitation period and long-term effects of rehabilitation after rotator cuff repair]. Nord Fysio. 2004;8(4):183-189. (Swe).
34 Wilcox RB, Harris BA, Arslanian LE, et al. Functional outcomes following rotator cuff repair based on tissue quality: a pilot study. (abstract). J Orthop Sporsts Phys Ther. Jan. 2006;36(1):a9-a10.

## Excluded – No Baseline Data (N = 89)

The following uncontrolled studies were excluded because no baseline data was reported.

1 Abrams JS. Arthroscopic techniques for massive rotator cuff repairs. Tech Shoulder Elbow Surg. 2007;8(3):126-134.
2 Altchek DW, Warren RF, Wickiewicz TL, et al. Arthroscopic acromioplasty: technique and results. J Bone Joint Surg Am. Sep. 1990;72(8):1198-1207. [pmid: 2398090].
3 Behrens P, Egbers HJ. Die fruhfunktionelle behandlung der verletzten schulter unterstutzt durch eine aktive schulterbandage. Aktuelle Traumatol. 1991;21(2):58-63. [pmid: 1677519].
4 Bittar ES. Arthroscopic management of massive rotator cuff tears. Arthroscopy. Nov. 2002;18(9 Suppl 2):104-106. [pmid: 12426534].
5 Bonutti PM, Cremens MJ, Lee FS, et al. Use of an allograft bone button for rotator cuff repair. Orthopedics. Feb. 2002;25(2):149-151. [pmid: 11866146].
6 Braune C, von Eisenhart-Rothe R, Welsch F, et al. Mid-term results and quantitative comparison of postoperative shoulder function in traumatic and non-traumatic rotator cuff tears. Arch Orthop Trauma Surg. Oct. 2003;123(8):419-424. [pmid: 14574601].
7 Budoff JE, Rodin D, Ochiai D, et al. Arthroscopic rotator cuff debridement without decompression for the treatment of tendinosis. Arthroscopy. Sep. 2005;21(9):1081-1089. [pmid: 16171633].
8 Chin PY, Sperling JW, Cofield RH, et al. Anterior acromioplasty for the shoulder impingement syndrome: long-term outcome. J Shoulder Elbow Surg. Nov. 2007;16(6):697-700. [pmid: 17950628].
9 Cordasco FA, Backer M, Craig EV, et al. The partial-thickness rotator cuff tear: is acromioplasty without repair sufficient?. Am J Sports Med. Mar. 2002;30(2):257-260. [pmid: 11912097].
10 Costouros JG, Porramatikul M, Lie DT, et al. Reversal of suprascapular neuropathy following arthroscopic repair of massive supraspinatus and infraspinatus rotator cuff tears. Arthroscopy. Nov. 2007;23(11):1152-1161. [pmid: 17986401].
11 Dawson J, Hill G, Fitzpatrick R, et al. Comparison of clinical and patient-based measures to assess medium-term outcomes following shoulder surgery for disorders of the rotator cuff. Arthritis Rheum. Oct. 15. 2002;47(5):513-519. [pmid: 12382300].
12 Ellman H. Diagnosis and treatment of incomplete rotator cuff tears. Clin Orthop Relat Res. 1990:64-74.
13 Essman JA, Bell RH, Askew M. Full-thickness rotator-cuff tear: an analysis of results. Clin Orthop Relat Res. Apr. 1991;(265):170-177.
14 Fealy S, Kingham TP, Altchek DW. Arthroscopically assisted (mini-open) rotator cuff repair. Sports Med Arthrosc. 1999;7(2):76-84.
15 Fealy S, Kingham TP, Altchek DW. Mini-open rotator cuff repair using a two-row fixation technique: outcomes analysis in patients with small, moderate, and large rotator cuff tears. Arthroscopy. Jul. 2002;18(6):665-670. [pmid: 12098132].
16 Fealy S, Adler RS, Drakos MC, et al. Patterns of vascular and anatomical response after rotator cuff repair. Am J Sports Med. Jan. 2006;34(1):120-127. [pmid: 16260468].
17 Feng S, Guo S, Nobuhara K, et al. Prognostic indicators for outcome following rotator cuff tear repair. J Orthop Surg. Dec. 2003;11(2):110-116.
18 Flynn LM. Shoulder impingement syndrome in recreational athletes. J Neurol Orthop Med Surg. 1990;11(2):111-114.
19 Fokter SK, Cicak N, Skorja J. Functional and electromyographic results after open rotator cuff repair. Clin Orthop Relat Res. Oct. 2003;(415):121-130.
20 Franceschi JP, Curvale G, Acquaviva P, et al. Traitement chirurgical des ruptures de la coiffe des rotateurs [Surgical treatment of ruptures of the rotator cuff]. Rev Rhum Mal Osteoartic. Jun. 1991;58(6):415-418. (Fre). [pmid: 1896781].
21 Gerber C, Krushell RJ. Isolated rupture of the tendon of the subscapularis muscle: clinical features in 16 cases. J Bone Joint Surg Br. May. 1991;73(3):389-394. [pmid: 1670434].
22 Getahun TY, MacDermid JC, Patterson SD. Concurrent validity of patient rating scales in assessment of outcome after rotator cuff repair. J Musculoskelet Res. 2000;4(2):119-127.
23 Gleyze P, Kempf JF. Orthopaedica Belgica B. Resultats cliniques et anatomiques d’ une serie de 20 ruptures de la coiffe des rotateurs reparees par agrafage endoscopique. Acta Orthop Belg. 1995;61:32-36. (Fre). [pmid: 8623604].
24 Goto M, Suzuki K, Shimada T. Relationship between lifestyle and shoulder motor function after reconstruction of rotator cuff tear. J Phys Ther. 2007;19(4):243-249.
25 Goutallier D, Postel JM. Influence de la degenerescence musculaire du supra-et de l’ infra-spinatus sur le pronostic des reparations chirurgicales de la coiffe des rotateurs. Acta Orthop Belg. 1998;64:42-45. (Fre). [pmid: 9922528].
26 Gualtieri G, Gualtieri I, Gagliardi S, et al. The results of the surgical treatment of breakage of the rotator cuff. Chir Organi Mov. Oct. 1991;76(4):335-339. [pmid: 1800045].
27 Habernek H, Schmid L, Frauenschuh E. Five year results of rotator cuff repair. Br J Sports Med. Dec. 1999;33(6):430-433. [pmid: 10597856].
28 Hambly N, Fitzpatrick P, MacMahon P, et al. Rotator cuff impingement: correlation between findings on MRI and outcome after fluoroscopically guided subacromial bursography and steroid injection. Am J Roentgenol. Nov. 2007;189(5):1179-1184. [pmid: 17954658].
29 Harryman DT, Mack LA, Wang KY, et al. Repairs of the rotator cuff: correlation of functional results with integrity of the cuff. J Bone Joint Surg Am. Aug. 1991;73(7):982-989. [pmid: 1874784].
30 Harryman DT, Hettrich CM, Smith KL, et al. A prospective multipractice investigation of patients with full-thickness rotator cuff tears: the importance of comorbidities, practice, and other covariables on self-assessed shoulder function and health status. J Bone Joint Surg Am. Apr. 2003;85(4):690-696. [pmid: 12672846].
31 Hoe-Hansen CE, Palm L, Norlin R. The influence of cuff pathology on shoulder function after arthroscopic subacromial decompression: a 3- and 6-year follow-up study. J Shoulder Elbow Surg. Nov. 1999;8(6):585-589. [pmid: 10633893].
32 Holibka R, Kalina R, Pach M, et al. Arthroscopic treatment of ruptures of the rotator cuff. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Dec. 2005;149(2):277-280. [pmid: 16601771].
33 Hollinshead RM, Mohtadi NG, Vande Guchte RA, et al. Two 6-year follow-up studies of large and massive rotator cuff tears: comparison of outcome measures. J Shoulder Elbow Surg. Sep. 2000;9(5):373-381. [pmid: 11075319].
34 Huber H. Debridement arthroscopique d’ une rupture degenerative massive de la coiffe des rotateurs. Rev Med Suisse Romande. 2004;124(5):261-263. (Fre).
35 Jacobs S, Williams H, Moir J, et al. Full thickness rotator cuff tears long-term follow-up. Eur J Orthop Surg Traumatol. 2000;10(1):61-64.
36 Jully JL, Autivy J, Joncour V. Objectifs hebdomadiares et surveillance de la rééducation des ruptures de coiffe opérées [Weekly objectives and monitoring rehabilitation of operated rotator cuff tears]. Ann Kinésithér. 1990;17(3):107-111. (Fre).
37 Kartus J, Kartus C, Rostgard-Christensen L, et al. Long-term clinical and ultrasound evaluation after arthroscopic acromioplasty in patients with partial rotator cuff tears. Arthroscopy. 2006;22(1):44-49. [pmid: 16399460].
38 Kempf JF, Mole D, Gleyze P, et al. Resultats du traitement endoscopique des tendinopathies de la coiffe des rotateurs (ruptures completes exclues). 1ere partie: Les tendinopathies non calcifiees [Results of endoscopic treatment of tendinopathies of the rotator cuff (excluding total ruptures). 1: non-calcifying tendinopathies]. Rev Chir Orthop Reparatrice Appar Mot. 1993;79(7):519-531. (Fre). [pmid: 8085034].
39 Kessler KJ, Bullens-Borrow AE, Zisholtz J. LactoSorb plates for rotator cuff repair. Arthroscopy. Mar. 2002;18(3):279-283. [pmid: 11877614].
40 Kilian O, Balser G, Heiss C, et al. Subjektives und klinisches outcome nach rekonstruktion der rotatorenmanschette im hoheren lebensalter [Subjective and clinical outcome after rotator cuff repair in elderly patients]. Z Orthop Unfallchir. Jul. 2008;146(4):471-477. (Ger).
41 Kim KC, Rhee KJ, Shin HD. Deformities associated with the suture-bridge technique for full-thickness rotator cuff tears. Arthroscopy. 2008;24(11):1251-7. [pmid: 18971055].
42 Kim KC, Rhee KJ, Shin HD, et al. Arthroscopic transosseous rotator cuff repair. Orthopedics. Apr. 2008;31(4):327-330. [pmid: 18453167].
43 Kulenkampff HA, Reichelt A. Der klinische verlauf der rotatorenmanschettenruptur nach konservativer therapie [Clinical course of ruptures of the rotator cuff after conservative therapy]. Orthop Prax. 1990;26(8):493-496. (Ger).
44 Kwon YW, Kalainov DM, Rose HA, et al. Management of early deep infection after rotator cuff repair surgery. J Shoulder Elbow Surg. Jan. 2005;14(1):1-5. [pmid: 15723006].
45 Kyrola K, Niemitukia L, Jaroma H, et al. Long-term MRI findings in operated rotator cuff tear. Acta radiol. Aug. 2004;45(5):526-533. [pmid: 15515515].
46 Lam F, Mok D. Open repair of massive rotator cuff tears in patients aged sixty-five years or over: is it worthwhile?. J Shoulder Elbow Surg. Sep. 2004;13(5):517-521. [pmid: 15383807].
47 Leroux JL, Hebert P, Mouilleron P, et al. Postoperative Shoulder Rotators Strength in Stage-Ii and Stage-Iii Impingement Syndrome. Clin Orthop Relat Res. 1995:46-54.
48 Lupo R, Benazzo F, Finardi E, et al. Surgery in massive ruptures of the rotator cuff: results as related to prognosis. Chir Organi Mov. Oct. 2000;85(4):389-394. [pmid: 11569363].
49 Lupo R, Rapisarda S, Bottinelli O, et al. Ultrasound and MRI for the long-term evaluation of surgical repair of the rotator cuffs. Chir Organi Mov. Jan. 2001;86(1):21-27. 50. [pmid: 12025099].
50 Mansat P, Cofield RH, Kersten TE, et al. Complications of rotator cuff repair. Orthop Clin North Am. Apr. 1997;28(2):205-213. [pmid: 9113716].
51 Marcon D, Paysant J. Place de la medecine physique et de readaptation avant et apres chirurgie reparatrice de la coiffe des rotateurs de l’ epaule : a propos d’ une revision a deux ans d’ une serie de 42 operes. Medecine physique et readaptation. Ann Med Nancy. 1997;36(5–6):299-305.
52 McFarland EG, Neira CA, Gutierrez MI, et al. Clinical significance of the arthroscopic drive-through sign in shoulder surgery. Arthroscopy. Jan. 2001;17(1):38-43. [pmid: 11154365].
53 McFarland EG, Park HB, Kim TK, et al. Limited lateral acromioplasty for rotator cuff surgery. Orthopedics. 2005;28(3):256-259. [pmid: 15790083].
54 Miller SL, Hazrati Y, Cornwall R, et al. Failed surgical management of partial thickness rotator cuff tears. Orthopedics. Nov. 2002;25(11):1255-1257. [pmid: 12452342].
55 Motycka T, Kriegleder B, Landsiedl F. Results of open repair of the rotator cuff: a long-term review of 79 shoulders. Arch Orthop Trauma Surg. 2001;121(3):148-151. [pmid: 11262780].
56 Neviaser RJ, Neviaser TJ, Neviaser JS. Anterior dislocation of the shoulder and rotator cuff rupture. Clin Orthop Relat Res. 1993;291(291):103-106. [pmid: 8504589].
57 Nobuhara K, Hata Y, Komai M. Surgical procedure and results of repair of massive tears of the rotator cuff. Clin Orthop Relat Res. Jul. 1994;(304):54-59.
58 Norlin R, Adolfsson L. Small full-thickness tears do well ten to thirteen years after arthroscopic subacromial decompression. J Shoulder Elbow Surg. Jan. 2008;17(1 Suppl):12S-16S. [pmid: 18201652].
59 Owens BD, Nelson BJ, Taylor DC. Acute brachial plexus compression after pectoralis major transfer for subscapularis insufficiency. Am J Sports Med. 2008;36(1):173-175. [pmid: 17641104].
60 Payne LZ, Altchek DW, Craig EV, et al. Arthroscopic treatment of partial rotator cuff tears in young athletes: a preliminary report. Am J Sports Med. May. 1997;25(3):299-305. [pmid: 9167807].
61 Petruccelli E, Cominetti G, Masse A. La riparazione della cuffia dei rotatori a cielo aperto: risultati a medio termine [Open repair of the rotator cuff tear: results at mean follow-up]. Minerva Ortop Traumatol. 2001;52:4-5. 217. 224. (Ita, Eng).
62 Plafki C, Hedtmann A, Fett H, et al. Ergebnisse der operativen therapie von rupturen der rotatorenmanschette der schulter [Results of surgical therapy of ruptures of the rotator cuff of the shoulder]. Z Orthop Ihre Grenzgeb. Jul. 1997;135(4):360-367. (Ger). [pmid: 9381775].
63 Porcellini G, Baccarani G, Campi F, et al. Isokinetic testing to evaluate patients submitted to surgery for the treatment of surgical lesion of the rotator cuff. Chir Organi Mov. Jul. 1996;81(3):295-302. [pmid: 9009413].
64 Razmjou H, Lincoln S, Axelrod T, et al. Factors contributing to failure of rotator cuff surgery in persons with work-related injuries. Physiother Can. 2008;60(2):125-133. [pmid: 20145776].
65 Reynolds SB, Dugas JR, Cain EL, et al. Debridement of small partial-thickness rotator cuff tears in elite overhead throwers. Clin Orthop Relat Res. Mar. 2008;466(3):614-621. [pmid: 18264849].
66 Riand N, Boulahia A, Walch G. Conflit postero-superieur de l’epaule chez le sportif: resultats du debridement arthroscopique [Posterosuperior impingement of the shoulder in the athlete: results of arthroscopic debridement in 75 patients]. Rev Chir Orthop Reparatrice Appar Mot. Feb. 2002;88(1):19-27. (Fre). [pmid: 11973531].
67 Rockwood CA, Lyons FR. Shoulder impingement syndrome: diagnosis, radiographic evaluation, and treatment with a modified neer acromioplasty. J Bone Joint Surg Am. 1993;75(3):409-424. [pmid: 8444920].
68 Romeo AA, Hang DW, Bach BR Jr, et al. Repair of full thickness rotator cuff tears: gender, age, and other factors affecting outcome. Clin Orthop Relat Res. Oct. 1999;(367):243-255.
69 Romeo AA, Cohen, Carreira DS. Traumatic anterior shoulder instability. Orthop Clin North Am. 2001;32(3):399-409. [pmid: 11888135].
70 Savoie FH. Costs analysis of successful rotator cuff repair surgery: an outcome study. Comparison of Gatekeeper system in surgical patients. Arthroscopy. 1995;11(6):672-676. [pmid: 8679026].
71 Schiepers P, Pauwels P, Penders W, et al. La place de l’arthroscopie dans la pathologie sous-acromiale: etude retrospective d’une serie d’acromioplasties arthroscopiques [The role of arthroscopy in subacromial pathology: retrospective study of a series of arthroscopic acromioplasties]. Acta Orthop Belg. Dec. 2000;66(5):438-448. (Fre). [pmid: 11196367].
72 Selvanetti A, Giombini A, Caruso I. Nonoperative treatment of partial-thickness rotator cuff tears in overhead athletes. Med Sci Sports Exerc. 1998;30(5 Suppl):S260.
73 Shen PH, Lien SB, Shen HC, et al. Long-term functional outcomes after repair of rotator cuff tears correlated with atrophy of the supraspinatus muscles on magnetic resonance images. J Shoulder Elbow Surg. Jan. 2008;17(1 Suppl):1S-7S. [pmid: 17931908].
74 Smith KL, Harryman DT, Antoniou J, et al. A prospective, multipractice study of shoulder function and health status in patients with documented rotator cuff tears. J Shoulder Elbow Surg. Sep. 2000;9(5):395-402. [pmid: 11075323].
75 Snyder S, Foos G. Arthroscopic treatment of bursal side and full thickness rotator cuff tears. Ann Chir Gynaecol. 1996;85(2):117-125. [pmid: 8817048].
76 Snyder SJ, Pachelli AF, Del PW, et al. Partial thickness rotator cuff tears: results of arthroscopic treatment. Arthroscopy. 1991;7(1):1-7. [pmid: 2009105].
77 Solomon DJ, Provencher MT, Bell SJ, et al. Arthroscopic rotator cuff repair in active duty military personnel: a young cohort of patients with rotator cuff tears. Oper Tech Sports Med. 2005;13(3):136-142.
78 Sonnery-Cottet B, Edwards TB, Noel E, et al. Rotator cuff tears in middle-aged tennis players: results of surgical treatment. Am J Sports Med. Jul. 2002;30(4):558-564. [pmid: 12130411].
79 Suenaga N, Minami A, Kaneda K. Postoperative subcoracoid impingement syndrome in patients with rotator cuff tear. J Shoulder Elbow Surg. Jul. 2000;9(4):275-278. [pmid: 10979521].
80 Theermann R, Refior HJ. Welche faktoren beeinflussen das ergebnis der rotatormanschetten-rekonstruktion [Factors influencing the result of reconstructions of the rotator cuff]. Orthop Prax. 1991;27(1):9-14. (Ger).
81 Walmsley RP, Hartsell H. Shoulder strength following surgical rotator cuff repair: a comparative analysis using Isokinetic testing. J Orthop Sporsts Phys Ther. 1992;15(5):215-222.
82 Warner JJP, Goitz RJ, Irrgang JJ, et al. Arthroscopic-assisted rotator cuff repair: patient selection and treatment outcome. J Shoulder Elbow Surg. Sep. 1997;6(5):463-472. [pmid: 9356936].
83 Weber SC. Arthroscopic debridement and acromioplasty versus mini-open repair in the management of significant partial-thickness tears of the rotator cuff. Orthop Clin North Am. Jan. 1997;28(1):79-82. [pmid: 9024433].
84 Weber SC. Arthroscopic debridement and acromioplasty versus mini-open repair in the treatment of significant partial-thickness rotator cuff tears. Arthroscopy. Mar. 1999;15(2):126-131. [pmid: 10210067].
85 Wolf EM, Pennington WT, Agrawal V. Arthroscopic rotator cuff repair: 4- to 10-year results. Arthroscopy. Jan. 2004;20(1):5-12. [pmid: 14716273].
86 Wolf EM, Pennington WT, Agrawal V. Arthroscopic side-to-side rotator cuff repair. Arthroscopy. 2005;21(7):881-887. [pmid: 16012503].
87 Worland RL. Treatment of rotator cuff impingement. Orthop Rev. 1993;22(1):76-79. [pmid: 8421637].
88 Wulker N, Melzer C, Wirth CJ. Shoulder surgery for rotator cuff tears: ultrasonographic 3-year follow-up of 97 cases. Acta Orthop Scand. Apr. 1991;62(2):142-147. [pmid: 2014724].
89 Zandi H, Coghlan JA, Bell SN. Mini-incision rotator cuff repair: a longitudinal assessment with no deterioration of result up to nine years. J Shoulder Elbow Surg. Mar. 2006;15(2):135-139. [pmid: 16517354].

## Excluded – Ineligible Study Design (N = 182)

The following studies were excluded because the study design did not meet the eligibility criteria. For the original review, these included before-and-after studies in which the data collection was either retrospective or unclear (n=142). For the review update, all uncontrolled studies were excluded, regardless of the direction of data collection (n=40).

1 Abbot AE, Li X, Busconi BD. Arthroscopic treatment of concomitant superior labral anterior posterior (SLAP) lesions and rotator cuff tears in patients over the age of 45 years. Am J Sports Med. 2009;37(7):1358-1362. [pmid: 19364887].
2 Adams CR, Schoolfield JD, Burkhart SS. The results of arthroscopic subscapularis tendon repairs. Arthroscopy. 2008;24(12):1381-1389. [pmid: 19038709].
3 Anderson K, Boothby M, Aschenbrener D, et al. Outcome and structural integrity after arthroscopic rotator cuff repair using 2 rows of fixation: minimum 2-year follow-up. Am J Sports Med. 2006;34(12):1899-1905. [pmid: 16870821].
4 Atkinson RN, Comley AS, Van EJ, et al. Successful early mobilization of major cuff repair using a suture post. J Shoulder Elbow Surg. Mar. 2006;15(2):183-187. [pmid: 16517361].
5 Auplish S, Funk L. Rotator cuff tears in athletes. Br J Hosp Med. 2009;70(5):271-275.
6 Balestro JC, Jacquot N. Resultats des tenotomies et des tenodeses du long biceps dans les lesions irreparables de la coiffe des rotateurs. Rev Chir Orthop Reparatrice Appar Mot. S42. 2007;93(8):5-5S. 48. (Fre). [pmid: 17389819].
7 Baudet B, Boussaton M. Resultats a long terme de la decompression sous-acromiale par arthroscopie, dans les larges ruptures de coiffe. J Traumatol Sport. 1997;14(4):212-216. (Fre).
8 Baydar M, Akalin E, El O, et al. The efficacy of conservative treatment in patients with full-thickness rotator cuff tears. Rheumatol Int. 2009;29(6):623-628. [pmid: 18850322].
9 Bellumore Y, Mansat M, Assoun J. Resultats de la chirurgie reparatrice de la coiffe des rotateurs: correlation radio-clinique [Results of the surgical repair of the rotator cuff: radio-clinical correlation]. Rev Chir Orthop Reparatrice Appar Mot. 1994;80(7):582-594. (Fre). [pmid: 7638384].
10 Berhouet J, Collin P, Benkalfate T, et al. Massive rotator cuff tears in patients younger than 65 years. Epidemiology and characteristics. Orthop Traumatol Surg Res. 2009;95(4 Suppl):13-18.
11 Bezer M, Kocaoglu B, Erol B, et al. Rotator kilif yirtiklarinda acik cerrahi onarimin uzun donem sonuclari [Long-term results of open surgical repair of rotator cuff tears]. Acta Orthop Traumatol Turc. 2004;38(2):110-114. (Tur). [pmid: 15129028].
12 Bigiliani LU, Kimmel J, McCann PD, et al. Repair of rotator cuff tears in tennis players. Am J Sports Med. 1992;20(2):112-117. [pmid: 1558235].
13 Bigliani LU, Cordasco FA, Mcllveen SJ, et al. Operative repair of massive rotator cuff tears. J Shoulder Elbow Surg. 1992;1:120-130.
14 Blevins FT, Warren RF, Cavo C, et al. Arthroscopic assisted rotator cuff repair: results using a mini-open deltoid splitting approach. Arthroscopy. 1996;12(1):50-59. [pmid: 8838729].
15 Bokor DJ, Hawkins RJ, Huckell GH, et al. Results of nonoperative management of full-thickness tears of the rotator cuff. Clin Orthop Relat Res. 1993:103-110.
16 Bond JL, Dopirak RM, Higgins J, et al. Arthroscopic replacement of massive, irreparable rotator cuff tears using a GraftJacket allograft: technique and preliminary results. Arthroscopy. 2008;24(4):403-409. [pmid: 18375271].
17 Boyle O, Glasson JM, Pollock RG, et al. Arthroscopically assisted rotator cuff repair with a limited portal-extension approach. Man Ther. 1999;4(1):44-48. [pmid: 10463021].
18 Brown TD, Newton PM, Steinmann SP, et al. Rotator cuff tears and associated nerve injuries. Orthopedics. 2000;23(4):329-332. [pmid: 10791582].
19 Bruns J, Henning R, Behrens P. Arthrolysis of the shoulder for ruptures of the rotator cuff. Int Orthop. 1997;21(3):157-160. [pmid: 9266293].
20 Burkhart SS. Arthroscopic debridement and decompression for selected rotator cuff tears: clinical results, pathomechanics, and patient selection based on biomechanical parameters. [Review]. Orthop Clin North Am. 1993;24(1):111-123. [pmid: 8421604].
21 Burkhart SS, Nottage WM, Ogilvie-Harris DJ, et al. Partial repair of irreparable rotator cuff tears. Arthroscopy. 1994;10(4):363-370. [pmid: 7945631].
22 Burkhart SS, Danaceau SM, Pearce CE. Arthroscopic rotator cuff repair: Analysis of results by tear size and by repair technique. Margin convergence versus direct tendon-to-bone repair. Arthroscopy. 2001;17(9):905-912. [pmid: 11694920].
23 Burkhart SS, Barth JR, Richards DP, et al. Arthroscopic repair of massive rotator cuff tears with stage 3 and 4 fatty degeneration. Arthroscopy. 2007;23(4):347-354. [pmid: 17418325].
24 Burns JP, Snyder SJ. Arthroscopic rotator cuff repair in patients younger than fifty years of age. J Shoulder Elbow Surg. 2008;17(1):90-66. [pmid: 18069008].
25 Calmet J, Esteve C, Mellado JM, et al. Rotura masiva del manguito de los rotadores: resultados del tratamiento quirurgico [Massive rupture of the rotator cuff: results of surgical treatment]. Rev Ortop Traumatol. 2002;46(4):294-299. (Spa).
26 Calmet J, Mellado JM, Garcia-Forcada IL, et al. MR Assessment of the Repaired Rotator Cuff in Patients Older than 65. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow. Athens. Sep 20–23, 2006.
27 Castagna A, Conti M, Markopoulos N, et al. Arthroscopic repair of rotator cuff tear with a modified Mason-Allen stitch: mid-term clinical and ultrasound outcomes. Knee Surg Sports Traumatol Arthrosc. May. 2008;16(5):497-503. [pmid: 18273602].
28 Castagna A, le Rose G, Conti M, et al. Predictive factors of subtle residual shoulder symptoms after transtendinous arthroscopic cuff repair a clinical study. Am J Sports Med. 2009;37(1):103-108. [pmid: 19059897].
29 Castanga A, Markopoulos N, Conti M, et al. Arthroscopic repair of full thickness rotator cuff tears using a modified Mason Allen stitch: clinical and sonographic results at two years follow up. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow. Athens. Sep 20–23, 2006.
30 Castricini R, Panfoli N, Nittoli R, et al. Transtendon arthroscopic repair of partial-thickness, articular surface tears of the supraspinatus: results at 2 years. Musculoskelet Surg. 2009;93(Suppl 1):S49-S54.
31 Chun JM, Kim SY, Kim JH. Arthroscopically assisted mini-deltopectoral rotator cuff repair. Orthopedics. 2008;31(1):74. [pmid: 19292164].
32 Ciampi P, Vitali M, Fraschini GF. Repair of massive rotator cuff tears in patients older than 65 years. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow. Athens. Sep 20–23, 2006.
33 Cicak N. [The results of the surgical treatment of rotator cuff tears]. Lijec Vjesn. 1998;120(12):365-369. [pmid: 19658357].
34 Clayton RA, Court-Brown CM. The epidemiology of musculoskeletal tendinous and ligamentous injuries. Injury. 2008;39(12):1338-1344. [pmid: 19036362].
35 Cole BJ, Alford W, Pylawka T, et al. Arthroscopic rotator cuff repair: prospective evaluation at minimum 2-year follow-up. 2006. Annual Meeting of the American Academy of Orthopaedic Surgeons. Chicago, IL. Mar 22–26, 2006.
36 Conti M, Garofalo R, Delle RG, et al. Postoperative rehabilitation after surgical repair of the rotator cuff. Musculoskelet Surg. 2009;93(Suppl 1):S55-S63.
37 Costouros JG, Porramatikul M, Lie DT, et al. Suprascapular neuropathy associated with massive rotator cuff tears: a rationale for arthroscopic rotator cuff repair. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow. Athens. Sep 20–23, 2006.
38 Cruz Lopez F, Gomez Espindola JC, Mazan Diaz A, et al. [Clinical-ultrasonographic assessment in arthroscopic rotator cuff repair after 1-year follow-up]. Acta Ortop Mex. 2009;23(1):9-14. [pmid: 19462766].
39 De BT, Dubuc JE, Joris D, et al. Results of arthroscopic acromioplasty for chronic rotator cuff lesion. Acta Orthop Belg. 2004;70(6):520-524. [pmid: 15669450].
40 Duralde XA, Bair B. Massive rotator cuff tears: the result of partial rotator cuff repair. J Shoulder Elbow Surg. 2005;14(2):121-127. [pmid: 15789003].
41 Duralde XA, Greene RT. Mini-open rotator cuff repair via an anterosuperior approach. J Shoulder Elbow Surg. 2008;17(5):715-721. [pmid: 18515153].
42 Edwards TB, Walch G, Sirveaux F, et al. Repair of tears of the subscapularis. J Bone Joint Surg Am. Apr. 2005;87(4):725-730. [pmid: 15805199].
43 Edwards TB, Walch G, Nove-Josserand L, et al. Arthroscopic debridement in the treatment of patients with isolated tears of the subscapularis. Arthroscopy. 2006;22(9):941-946. [pmid: 16952722].
44 Edwards TB, Walch G, Sirveaux F, et al. Repair of tears of the subscapularis: surgical technique. [Review]. J Bone Joint Surg Am. 2006;88(Suppl 1):1-10. [pmid: 16510795].
45 El-Zahaar MS, Bebars M. The value of the continuous passive motion after repair of the rotator cuff tear in athletes (an arthroscopic study). J Neurol Orthop Med Surg. 1995;16(4):246-252.
46 Erol O, Ozcakar L, Celiker R. Shoulder rotator strength in patients with stage I-II subacromial impingement: relationship to pain, disability, and quality of life. J Shoulder Elbow Surg. 2008;17(6):893-897. [pmid: 18774737].
47 Farron A, De RB. Chirurgie de la coiffe des rotateurs: indications et resultats [Surgery of the rotator cuff: indications and results]. Rev Med Suisse Romande. Aug. 1992;112(8):691-694. (Fre). [pmid: 1411024].
48 Flurin PH, Landreau P. Societe francaise d’artroscopie. Reparation arthroscopique des lesions transfixiantes de la coiffe: etude retrospective multicentrique de 576 cas. Congres: Dix-huitieme journee de Bichat, “appareil locomoteur”. 28 janvier 2005. Seance pleniere. Rhumatologie. 2005;57(1):19-25.
49 Flurin PH, Landreau P, Boileau P, et al. Arthroscopic rotator cuff repair. Correlations of clinical results with integrity of the tendon. 2006. Annual Meeting of the American Academy of Orthopaedic Surgeons. Chicago, IL. Mar 22–26, 2006.
50 Flurin PH, Landreau P, Gregory T, et al. Cuff integrity after arthroscopic rotator cuff repair: correlation with clinical results in 576 cases. Arthroscopy. 2007;23(4):340-346.
51 Flury MP, John M, Goldhahn J, et al. Rupture of the subscapularis tendon (isolated or in combination with supraspinatus tear): when is a repair indicated?. J Shoulder Elbow Surg. 2006;15(6):659-664. [pmid: 17055750].
52 Frank A. Ruptures transfixiantes de la coiffe des rotateurs: décompression sous-acromiale sans réparation: Quelles coiffes faut-il réparer et comment? [Transfixing ruptures of the rotator cuff: subacromial decompression without repair: cuff selection and repair techniques]. Rhumatologie. 2002;54(2):16-24. (Fre).
53 Frank JB, ElAttrache NS, Dines JS, et al. Repair site integrity after arthroscopic transosseous-equivalent suture-bridge rotator cuff repair. Am J Sports Med. 2008;36(8):1496-1503. [pmid: 18658021].
54 Galatz LM, Ball CM, Teefey SA, et al. The outcome and repair integrity of completely arthroscopically repaired large and massive rotator cuff tears. J Bone Joint Surg Am. 2004;86(2):219-224. [pmid: 14960664].
55 Gartsman GM. Arthroscopic acromioplasty for lesions of the rotator cuff. J Bone Joint Surg Am. 1990;72(2):169-180. [pmid: 2303503].
56 Gartsman GM, Milne JC. Articular surface partial-thickness rotator cuff tears. J Shoulder Elbow Surg. 1995;4(6):409-415. [pmid: 8665284].
57 Gartsman GM, Khan M, Hammerman SM. Arthroscopic repair of full-thickness tears of the rotator cuff. J Bone Joint Surg Am. 1998;80(6):832-840. [pmid: 9655101].
58 Gazielly DF, Gleyze P, Montagnon C, et al. Resultats fonctionnels et anatomiques apres traitement chirurgical des ruptures de la coiffe des rotateurs. 2eme partie: evaluation fonctionnelle et anatomique postoperatoire des ruptures de la coiffe des rotateurs [Functional and anatomical results after surgical treatment of ruptures of the rotator cuff. 2: postoperative functional and anatomical evaluation of ruptures of the rotator cuff]. Rev Chir Orthop Reparatrice Appar Mot. 1995;81(1):17-26. (Fre). [pmid: 7569174].
59 Gerber C, Hersche O, Farron A. Isolated rupture of the subscapularis tendon. J Bone Joint Surg Am. 1996;78(7):1015-1023. [pmid: 8698718].
60 Gerber C, Fuchs B, Hodler J. The results of repair of massive tears of the rotator cuff. J Bone Joint Surg Am. 2000;82(4):505-515. [pmid: 10761941].
61 Gleyze P, Otero F, Kempf JF. Ruptures de la coiffe des rotateurs de l’epaule: traitement symptomatique par acromioplastie sous arthroscopie: resultats et analyse des 31 premiers cas [Rotator cuff tears: symptomatic treatment by arthroscopic subacromal decompression: results and analysis of the 31 first cases]. Rhumatologie. 1995;47(2):37-46. (Fre).
62 Gleyze P, Thomazeau H, Flurin PH, et al. Reparation endoscopique des ruptures de la coiffe des rotateurs [Arthroscopic rotator cuff repair: a multicentric retrospective study of 87 cases with anatomical assessment]. Rev Chir Orthop Reparatrice Appar Mot. 2000;86(6):566-574. (Fre). [pmid: 11060430].
63 Goldberg BA, Nowinski RJ, Matsen FA III. Outcome of nonoperative management of full-thickness rotator cuff tears. Clin Orthop Relat Res. 2001:99-107.
64 Goldberg BA, Lippitt SB, Matsen FA III. Improvement in comfort and function after cuff repair without acromioplasty. Clin Orthop Relat Res. 2001:142-150.
65 Goutallier D, Postel JM, Lavau L, et al. Influence de la degenerescence graisseuse des muscles supraepineux et infraepineux sur le pronostic des reparations chirurgicales de la coiffe des rotateurs [Impact of fatty degeneration of the suparspinatus and infraspinatus msucles on the prognosis of surgical repair of the rotator cuff]. Rev Chir Orthop Reparatrice Appar Mot. 1999;85(7):668-676. (Fre). [pmid: 10612130].
66 Goutallier D, Postel JM, Gleyze P, et al. Influence of cuff muscle fatty degeneration on anatomic and functional outcomes after simple suture of full-thickness tears. J Shoulder Elbow Surg. 2003;12(6):550-554. [pmid: 14671517].
67 Grondel RJ, Savoie FH III, Field LD. Rotator cuff repairs in patients 62 years of age or older. J Shoulder Elbow Surg. 2001;10(2):97-99. [pmid: 11307069].
68 Goutallier D, Postel JM, Radier C, et al. Long-term functional and structural outcome in patients with intact repairs 1 year after open transosseous rotator cuff repair. J Shoulder Elbow Surg. 2009;18(4):521-528. [pmid: 19213574].
69 Green A, Bradley MP, Tocci SL, et al. Patient satisfaction after rotator cuff repair. 2006. Annual Meeting of the American Academy of Orthopaedic Surgeons. Chicago, IL. Mar 22–26, 2006.
70 Habernek H, Weinstabl R, Schabus R, et al. A new approach to the subacromial space: technique and 2-year results in 28 rotator-cuff repair cases. Acta Orthop Scand. 1993;64(1):92-94. [pmid: 8451960].
71 Hanusch BC, Goodchild L, Finn P, et al. Large and massive tears of the rotator cuff: functional outcome and integrity of the repair after a mini-open procedure. J Bone Joint Surg Br. 2009;91(2):201-205. [pmid: 19190054].
72 Hardy P, Duparc J. Chirurgie arthroscopique reparatrice de la coiffe des rotateurs (sous-scapulaire exclu). Conferences d’enseignement 2006. Cahiers d’enseignement de la SOFCOT. 2006;91:1-23. (Fre).
73 Hata Y, Saitoh S, Murakami N, et al. Volume changes of supraspinatus and infraspinatus muscles after supraspinatus tendon repair: a magnetic resonance imaging study. J Shoulder Elbow Surg. 2005;14(6):631-635. [pmid: 16337532].
74 Hattrup SJ. Rotator cuff repair: relevance of patient age. J Shoulder Elbow Surg. 1995;4(2):95-100. [pmid: 7600171].
75 Hawkins RJ, Morin WD, Bonutti PM. Surgical treatment of full-thickness rotator cuff tears in patients 40 years of age or younger. J Shoulder Elbow Surg. 1999;8(3):259-265. [pmid: 10389083].
76 Henn RF III, Kang L, Tashjian RZ, et al. Patients’ preoperative expectations predict the outcome of rotator cuff repair. J Bone Joint Surg Am. 2007;89(9):1913-1919. [pmid: 17768186].
77 Hersch JC, Sgaglione NA. Arthroscopically assisted mini-open rotator cuff repairs: functional outcome at 2- to 7-year follow-up. Am J Sports Med. 2000;28(3):301-311. [pmid: 10843119].
78 Hirooka A, Yoneda M, Wakaitani S, et al. Augmentation with a Gore-Tex patch for repair of large rotator cuff tears that cannot be sutured. J Orthop Sci. 2002;7(4):451-456. [pmid: 12181658].
79 Huberty DP, Schoolfield JD, Brady PC, et al. Incidence and treatment of postoperative stiffness following arthroscopic rotator cuff repair. Arthroscopy. 2009;25(8):880-890. [pmid: 19664508].
80 Huijsmans PE, Pritchard MP, Berghs BM, et al. Arthroscopic rotator cuff repair with double-row fixation. J Bone Joint Surg Am. 2007;89(6):1248-1257. [pmid: 17545428].
81 Iossifidis A, Gill I. Results of arthroscopic rotator cuff repair. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow. Athens. Sep 20–23, 2006.
82 Ito Y, Nakao Y, Tomo H, et al. Significance of the muscular power evaluation with isokinetic dynamometer in shoulders with rotator cuff tears. 52nd Annual Meeting of the Orthopaedic Research Society. Chicago, IL. Mar 19–22, 2006.
83 Itoi E, Tabata S. Conservative treatment of rotator cuff tears. Clin Orthop Relat Res. 1992:165-173.
84 Itoi E, Tabata S. Rotator cuff tears in anterior dislocation of the shoulder. Int Orthop. 1992;16(3):240-244. [pmid: 1428335].
85 Itoi E, Tabata S. Incomplete rotator cuff tears: results of operative treatment. Clin Orthop Relat Res. 1992:128-135.
86 Jaffe M, Frank A, Beaufils P. L’acromioplastie endoscopique dans les ruptures completes de la coiffe des rotateurs [Endoscopic acromioplasty in total rupture of the rotator cuff]. Rev Chir Orthop Reparatrice Appar Mot. 1994;80(5):369-738. (Fre). [pmid: 7746922].
87 Jiang CY, Feng H, Hong L, et al. Arthroscopic rotator cuff repair for the treatment of rotator cuff tear. Zhonghua Wai Ke Za Zhi. 2006;44(4):249-253. (Chi). [pmid: 16635369].
88 Jones CK, Savoie FH. Arthroscopic repair of large and massive rotator cuff tears. Arthroscopy. 2003;19(6):564-571. [pmid: 12861193].
89 Juvenspan M, Conso C, Gaudin P, et al. Rupture isolee du tendon du muscle subscapularis: resultats des reparations a ciel ouvert [Isolated tear of the subscapularis tendon: results of open repair]. J Traumatol Sport. 2005;22(1):5-12. (Fre).
90 Kamath G, Galatz LM, Keener JD, et al. Tendon integrity and functional outcome after arthroscopic repair of high-grade partial-thickness supraspinatus tears. J Bone Joint Surg Am. 2009;91(5):1055-1062. [pmid: 19411453].
91 Kempf JF, Gleyze P, Bonnomet F, et al. A multicenter study of 210 rotator cuff tears treated by arthroscopic acromioplasty. Arthroscopy. 1999;15(1):56-66. [pmid: 10024034].
92 Kim SH, Oh I, Park JS, et al. Intra-articular repair of an isolated partial articular-surface tear of the subscapularis tendon. Am J Sports Med. 2005;33(12):1825-1830. [pmid: 16157850].
93 Kim SJ, Lee JW, Kim BS. Arthroscopic decompression for subacromial impingement syndrome. J Korean Med Sci. 1997;12(2):123-127. [pmid: 9170017].
94 Kreuz PC, Remiger A, Erggelet C, et al. Isolated and combined tears of the subscapularis tendon. Am J Sports Med. 2005;33(12):1831-1837. [pmid: 16157858].
95 Krishnan SG, Harkins DC, Schiffern SC, et al. Arthroscopic repair of full-thickness tears of the rotator cuff in patients younger than 40 years. Arthroscopy. 2008;24(3):324-328. [pmid: 18308185].
96 Kronberg M, Wahlstrom P, Brostrom LA. Shoulder function after surgical repair of rotator cuff tears. J Shoulder Elbow Surg. 1997;6(2):125-130. [pmid: 9144599].
97 Lahteenmaki HE, Virolainen P, Hiltunen A, et al. Results of early operative treatment of rotator cuff tears with acute symptoms. J Shoulder Elbow Surg. 2006;15(2):148-153. [pmid: 16517356].
98 Lahteenmaki HE, Hiltunen A, Virolainen P, et al. Repair of full-thickness rotator cuff tears is recommended regardless of tear size and age: a retrospective study of 218 patients. J Shoulder Elbow Surg. 2007;16(5):586-590. [pmid: 17513136].
99 Lee E, Bishop JY, Braman JP, et al. Outcomes after arthroscopic rotator cuff repairs. J Shoulder Elbow Surg. 2007;16(1):1-5. [pmid: 17011216].
100 Levy HJ, Uribe JW, Delaney LG. Arthroscopic assisted rotator cuff repair: preliminary results. Arthroscopy. 1990;6(1):55-60. [pmid: 2310453].
101 Levy HJ, Gardner RD, Lemak LJ. Arthroscopic subacromial decompression in the treatment of full-thickness rotator cuff tears. Arthroscopy. 1991;7(1):8-13. [pmid: 2009126].
102 Lichtenberg S, Liem D, Magosch P, et al. Influence of tendon healing after arthroscopic rotator cuff repair on clinical outcome using single row Mason-Allen suture technique - a prospective, MRI controlled study. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow. Athens. Sep 20–23, 2006.
103 Liem D, Alci S, Dedy N, et al. Clinical and structural results of partial supraspinatus tears treated by subacromial decompression without repair. Knee Surg Sports Traumatol Arthrosc. 2008;16(10):967-972. [pmid: 18712359].
104 Liem D, Lengers N, Dedy N, et al. Arthroscopic debridement of massive irreparable rotator cuff tears. Arthroscopy. 2008;24(7):743-748. [pmid: 18589261].
105 Liu SH, Baker CL. Arthroscopically assisted rotator cuff repair: correlation of functional results with integrity of the cuff. Arthroscopy. 1994;10(1):54-60. [pmid: 8166903].
106 Liu SH. Arthroscopically-assisted rotator-cuff repair. J Bone Joint Surg Br. 1994;76(4):592-595. [pmid: 8027147].
107 Lo I, Burkhart SS. Arthroscopic revision of rotator cuff repairs of failed repairs of the rotator cuff. Arthroscopy Association of North America 22nd Annual Meeting. Phoenix, AZ. Apr 24–28, 2003.
108 Maman E, Harris C, White L, et al. Outcome of nonoperative treatment of symptomatic rotator cuff tears monitored by magnetic resonance imaging. J Bone Joint Surg Am. 2009;91(8):1898-1906. [pmid: 19651947].
109 Mansat P, Frankle M, Cofield RH. Les lesions du tendon du subscapulaire: etude descriptive et resultats des reparations chirurgicales. Rev Rhum Ed Fr. 2003;70(9):720-726. (Fre).
110 Mansat P, Frankle MA, Cofield RH. Tears in the subscapularis tendon: descriptive analysis and results of surgical repair. Joint Bone Spine. 2003;70(5):342-347. [pmid: 14563461].
111 Marc T. Le traitement fonctionnel des ruptures de coiffe: protocole et resultats chez un groupe de 21 patients. XVIIe Journees de reeducation de la main et du membre superieur. Paris. 18–19, janvier 2002. Kinesither Sci. 2001:46-48. (Fre).
112 Massoud SN, Levy O, Copeland SA. Subacromial decompression: treatment for small- and medium-sized tears of the rotator cuff. J Bone Joint Surg Br. 2002;84(7):955-960. [pmid: 12358385].
113 Maynou C, Mehdi N, Cassagnaud X, et al. Resultats de la tenotomie arthroscopique du chef long du biceps brachial dans les ruptures transfixiantes de la coiffe des rotateurs non reparees: a propos de 40 cas [Clinical results of arthroscopic tenotomy of the long head of the biceps brachii in full thickness tears of the rotator cuff without repair: 40 cases]. Rev Chir Orthop Reparatrice Appar Mot. 2005;91(4):300-306. (Fre). [pmid: 16158544].
114 McIntyre LF, Norris M, Weber B. Comparison of suture welding and hand-tied knots in mini-open rotator cuff repair. Arthroscopy. 2006;22(8):833-836. [pmid: 16904579].
115 Melis B, Nemoz C, Walch G. Muscle fatty infiltration in rotator cuff tears: Descriptive analysis of 1688 cases. Orthop Traumatol Surg Res. 2009;95(5):319-324. [pmid: 19586809].
116 Mellado JM, Calmet J, Olona M, et al. Surgically repaired massive rotator cuff tears: MRI of tendon integrity, muscle fatty degeneration, and muscle atrophy correlated with intraoperative and clinical findings. Am J Roentgenol. 2005;184(5):1456-1463. [pmid: 15855096].
117 Millar AL, Lasheway PA, Eaton W, et al. A retrospective, descriptive study of shoulder outcomes in outpatient physical therapy. J Orthop Sports Phys Ther. 2006;36(6):403-414. [pmid: 16776489].
118 Moore DR, Cain EL, Schwartz ML, et al. Allograft reconstruction for massive, irreparable rotator cuff tears. Am J Sports Med. 2006;34(3):392-396. [pmid: 16260463].
119 Moulinoux P, Clavert P, Dagher E, et al. Arthroscopic repair of rotator cuff tears. Oper Orthop Traumatol. 2007;19(3):231-254. [pmid: 17728983].
120 Murray TF Jr, Lajtai G, Mileski RM, et al. Arthroscopic repair of medium to large full-thickness rotator cuff tears: outcome at 2- to 6-year follow-up. J Shoulder Elbow Surg. 2002;11(1):19-24. [pmid: 11845144].
121 Musil D, Sadovsky P, Stehlik J. Masivni ruptura rotatorove manzety: srovnani mini-open a artroskopicke rekonstrukce. Cast 1. Mini-open technika [Massive tears of rotator cuff: comparison of mini-open and arthroscopic techniques. Part 1. Mini-open technique]. Acta Chir Orthop Traumatol Cech. 2006;73(6):387-393. (Cze). [pmid: 17266840].
122 Nakamura N, Ito Y, Tomo H, et al. Second look arthroscopic evaluation for mini-open rotator cuff repair. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow. Athens. Sep 20–23, 2006.
123 Namdari S, Henn RF III, Green A. Traumatic anterosuperior rotator cuff tears: the outcome of open surgical repair. J Bone Joint Surg Am. 2008;90(9):1906-1913. [pmid: 18762651].
124 Neri BR, Vollmer EA, Kvitne RS. Isolated type II superior labral anterior posterior lesions: age-related outcome of arthroscopic fixation. Am J Sports Med. 2009;37(5):937-942. [pmid: 19229044].
125 Nho SJ, Shindle MK, Adler RS, et al. Prospective analysis of arthroscopic rotator cuff repair: subgroup analysis. J Shoulder Elbow Surg. 2009;18(5):697-704. [pmid: 19269861].
126 Oh JH, Kim SH, Ji HM, et al. Prognostic factors affecting anatomic outcome of rotator cuff repair and correlation with functional outcome. Arthroscopy. 2009;25(1):30-39. [pmid: 19111216].
127 Oizumi N, Suenaga N, Fukuda K, et al. Massive rotator cuff tears repaired on top of humeral head by McLaughlin’s procedure. J Shoulder Elbow Surg. 2007;16(3):321-326. [pmid: 17188911].
128 Olsewski JM, Depew AD. Arthroscopic subacromial decompression and rotator cuff debridement for stage II and stage III impingement. Arthroscopy. 1994;10(1):61-68. [pmid: 8166904].
129 Orthopaedic residents & fellows’ conference. South Med J. 1994;87(9):S76.
130 Ozbaydar MU, Tonbul M, Yalaman O. Rotator mansetin tam kat yirtiklarinda artroskopik tamir sonuclari [The results of arthroscopic repair of full-thickness tears of the rotator cuff]. Acta Orthop Traumatol Turc. 2005;39(2):114-120. (Tur). [pmid: 15925933].
131 Ozbaydar MU, Tonbul M, Yurdoglu C, et al. Rotator manset yirtiklarinin artroskopik yardimli mini-acik yontemle tamiri [Arthroscopic-assisted mini-open repair of rotator cuff tears]. Acta Orthop Traumatol Turc. 2005;39(2):121-127. (Tur). [pmid: 15925934].
132 Ozbaydar MU, Tonbul M, Tekin AC, et al. Artroskopik rotator manset onarimi: sonuclar ve belirleyici faktorlerin analizi [Arthroscopic rotator cuff repair: evaluation of outcomes and analysis of prognostic factors]. Acta Orthop Traumatol Turc. 2007;41(3):169-174. (Tur). [pmid: 17876114].
133 Papacharalampous X, Maris JS, Ferousis J, Primetis H, et al. Magnetic resonance imaging for the evaluation of rotator cuff lesions. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow. Athens. Sept 20–23, 2006.
134 Park TS, Kim TS. Comparative study of arthroscopic treatment of full thickness rotator cuff tear with or without frozen shoulder. Arthroscopy Association of North America 23rd Annual Meeting. Orlando, FL. Apr 22–25, 2004.
135 Park JY, Levine WN, Marra G, et al. Portal-extension approach for the repair of small and medium rotator cuff tears. Am J Sports Med. 2000;28(3):312-316. [pmid: 10843120].
136 Park JY, Yoo MJ, Kim MH. Comparison of surgical outcome between bursal and articular partial thickness rotator cuff tears. Orthopedics. 2003;26(4):387-90. [pmid: 12722909].
137 Paulos LE, Meislin RJ, Drawbert J. The acromion-splitting approach for large and massive rotator cuff tears. Am J Sports Med. 1994;22(3):306-312. [pmid: 8037268].
138 Paulos LE, Kody MH. Arthroscopically enhanced “miniapproach” to rotator cuff repair. Am J Sports Med. 1994;22(1):19-25. [pmid: 8129104].
139 Pfahler M, Branner S, Refior HJ. Die komplette rotatorenmanschettenruptur: differenzierte op-techniken und mittelfristige ergebnisse [Complete rotator cuff rupture: differential surgical techniques and intermediate-term results]. Z Orthop Ihre Grenzgeb. 1999;137(4):295-300. (Ger). [pmid: 11051013].
140 PL-RR-268-SA. Phys Ther. 1998;78(5):S88.
141 Porat S, Nottage WM, Fouse MN. Repair of partial thickness rotator cuff tears: a retrospective review with minimum two-year follow-up. J Shoulder Elbow Surg. 2008;17(5):729-731. [pmid: 18619864].
142 Posada A, Uribe JW, Hechtman KS, et al. Mini-deltoid splitting rotator cuff repair: do results deteriorate with time?. Arthroscopy. 2000;16(2):137-141. [pmid: 10705323].
143 Postel JM, Goutallier D, Baldoncini J. Traitement des ruptures associees des supra-epineux et infra-epineux par suture apres avancement tendino-musculaire [Treatment of associated ruptures of supraspinatus and infraspinatus by suture with musculo tendinous advancement]. Rev Chir Orthop Reparatrice Appar Mot. S162. 2004;90(5 Suppl):1-1S. 166 (Fre).
144 Ratti C, Murena L, Surace MF, et al. Clinical and ultrasound results after arthroscopic repair of the rotator cuff. Chir Organi Mov. 2005;90(2):95-104. [pmid: 16422234].
145 Rebuzzi E, Coletti N, Schiavetti S, et al. Arthroscopic rotator cuff repair in patients older than 60 years. Arthroscopy. 2005;21(1):48-54. [pmid: 15650666].
146 Roye RP, Grana WA, Yates CK. Arthroscopic subacromial decompression: two- to seven-year follow-up. Arthroscopy. 1995;11(3):301-306. [pmid: 7632306].
147 Ryu RK. Arthroscopic subacromial decompression: a clinical review. Arthroscopy. 1992;8(2):141-147. [pmid: 1637423].
148 Saragaglia D, Montbarbon E, Picard F, et al. Les ruptures isolees du tendon du muscle supra-epineux: resultats de 49 reparations chirurgicales [Isolated rupture of the tendon of the supra spinatus muscle: results of 49 surgical repair]. Rev Chir Orthop Reparatrice Appar Mot. 1995;81(7):575-580. (Fre). [pmid: 8729802].
149 Saragaglia D, Montbarbon E, Picard F, et al. Les ruptures isolees du tendon du muscle supra-epineux: isolated teas of supra-spinatus. Rhumatologie. 1995;47(6):213-217. (Fre).
150 Shinners TJ, Noordsij PG, Orwin JF. Arthroscopically assisted mini-open rotator cuff repair. Arthroscopy. 2002;18(1):21-26. [pmid: 11774137].
151 Sperling JW, Cofield RH, Schleck C. Rotator cuff repair in patients fifty years of age and younger. J Bone Joint Surg Am. 2004;86(10):2212-2215. [pmid: 15466730].
152 Suenaga N, Minami A. Coracoacromial arch decompression in rotator cuff surgery. Int Orthop. 2000;24(4):212-216. [pmid: 11081843].
153 Sugaya H, Maeda K, Moriishi J, et al. Repair integrity and functional outcome after arthroscopic double-row rotator cuff repair. J Bone Joint Surg. 2007;89(5):953-960. [pmid: 17473131].
154 Sukthankar A, Nyffeler RW, Werner CML, Gerber C. Lateral Extension of the Acromion and Rotator Cuff Tears. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow. Athens. Sep 20–23, 2006.
155 Tauber M, Koller H, Resch H. Transosseous arthroscopic repair of partial articular-surface supraspinatus tendon tears. Knee Surg Sports Traumatol Arthrosc. 2008;16(6):608-613. [pmid: 18418574].
156 Tauro JC. Arthroscopic rotator cuff repair: analysis of technique and results at 2- and 3-year follow-up. Arthroscopy. 1998;14(1):45-51. [pmid: 9486332].
157 Tauro JC. Long term results of arthroscopic rotator cuff repair. Arthroscopy Association of North America 23rd Annual Meeting. Orlando, FL. Apr 22–25, 2004.
158 Thomazeau H, Gleyze P, Frank A, et al. Le debridement endoscopique des ruptures transfixiantes de la coiffe des rotateurs: etude retrospective multicentrique de 283 cas a plus de 3 ans de recul [Arthroscopic debridement of full-thickness tears of the rotator cuff: a retrospective multicenter study of 283 cases with 3-year follow-up]. Rev Chir Orthop Reparatrice Appar Mot. 2000;86(2):136-142. (Fre). [pmid: 10804410].
159 Thomazeau H, Gleyze P. Le traitement par deridement arthroscopique des ruptures associes des supra et infraspinatus non rearables par suture directe [Treatment by arthroscopic debridement of the associated ruptures of supraspinatus and infraspinatus unrepairable by direct suture]. Rev Chir Orthop Reparatrice Appar Mot. S166. 2004;90(5 Suppl):1-168. (Fre).
160 Van Linthoudt D, Deforge J, Malterre L, et al. Suture de la coiffe des rotateurs: resultats a long terme. Rev Rhum Ed Fr. 2003;70(7):582-587. (Fre).
161 Van Linthoudt D, Deforge J, Malterre L, et al. Rotator cuff repair: long-term results. Joint Bone Spine. 2003;70(4):271-275. [pmid: 12951309].
162 Van Riet RP, O’Leary ST, Hooper A, et al. Rotator cuff strength following open subscapularis tendon repair. Acta Orthop Belg. 2008;74(2):173-179. [pmid: 18564471].
163 Visuri T, Kiviluoto O, Eskelin M. Carbon fiber for repair of the rotator cuff: a 4-year follow-up of 14 cases. Acta Orthop Scand. 1991;62(4):356-359. [pmid: 1882676].
164 Vives MJ, Miller LS, Rubenstein DL, et al. Repair of rotator cuff tears in golfers. Arthroscopy. 2001;17(2):165-172. [pmid: 11172246].
165 Voos JE, Pearle AD, Mattern CJ, et al. Outcomes of combined arthroscopic rotator cuff and labral repair. Am J Sports Med. 2007;35(7):1174-1179. [pmid: 17387217].
166 Walch G, Marechal E, Maupas J, et al. Traitement chirurgical des ruptures de la coiffe des rotateurs: facteurs de pronostic [Surgical treatment of rotator cuff rupture: prognostic factors]. Rev Chir Orthop Reparatrice Appar Mot. 1992;78(6):379-388. (Fre). [pmid: 1304637].
167 Walch G, Marechal E. Traitement chirurgical des ruptures de la coiffe des rotateurs: facteurs de pronostic [Surgical treatment of rotator cuff tears]. Rev Chir Orthop Reparatrice Appar Mot. 1992;78(6):379-388. (Fre). [pmid: 1304637].
168 Walch G, Edwards TB, Boulahia A, et al. Arthroscopic tenotomy of the long head of the biceps in the treatment of rotator cuff tears: clinical and radiographic results of 307 cases. J Shoulder Elbow Surg. 2005;14(3):238-246. [pmid: 15889020].
169 Wasilewski SA, Frankl U. Rotator cuff pathology: arthroscopic assessment and treatment. Clin Orthop Relat Res. 1991:65-70.
170 Watson EM, Sonnabend DH. Outcome of rotator cuff repair. J Shoulder Elbow Surg. 2002;11(3):201-211. [pmid: 12070490].
171 Wessel RN, Rasenberg EJJ, Guldemond NA, et al. Arthroscopic Rotator Cuff Repair: Clinical Results. 53rd Congress of the Nordic Orthopaedic Federation. Oslo (Norway). May 31-Jun 2, 2006.
172 Wirth MA, Basamania C, Rockwood CA Jr. Nonoperative management of full-thickness tears of the rotator cuff. Orthop Clin North Am. 1997;28(1):59-67. [pmid: 9024431].
173 Wirth MA. Nonoperative management of full-thickness tears of the rotator cuff. The rotator cuff, Part I. Orthop Clin North Am. 1997;28(1):59-67. [pmid: 9024431].
174 Worland RL, Arredondo J, Angles F, et al. Repair of massive rotator cuff tears in patients older than 70 years. J Shoulder Elbow Surg. Jan. 1999;8(1):26-30. [pmid: 10077792].
175 Wright SA, Cofield RH. Management of partial-thickness rotator cuff tears. J Shoulder Elbow Surg. Nov. 1996;5(6):458-466. [pmid: 8981271].
176 Yamanaka K, Matsumoto T. The joint side tear of the rotator cuff: a follow up study by arthrography. Clin Orthop Relat Res. Jul. 1994;(304):68-73.
177 Yel M, Shankwiler JA, Noonan JE Jr, et al. Results of decompression and rotator cuff repair in patients 65 years old and older: 6- to 14-year follow-up. Am J Orthop. Apr. 2001;30(4):347-352. [pmid: 11334458].
178 Yoo JC, Ahn JH, Yang JH, et al. Correlation of Arthroscopic Repairability of Large to Massive Rotator Cuff Tears With Preoperative Magnetic Resonance Imaging Scans. Arthroscopy - Journal of Arthroscopic and Related Surgery. 2009;25(6):573-582.
179 Yoo JC, Kim JH, Lee YS, et al. Arthroscopic double mattress repair in incomplete subscapularis tears. Orthopedics. 2008;31(9):851-854. [pmid: 18814591].
180 Zanchi A, Minati S, Boi M, et al. La ricostruzione a cielo aperto nelle rotture massive inveterate della cuffia dei rotatori [The opened reconstruction in the inveterate massive tears of the rotator cuff: our experience]. Minerva Ortop Traumatol. 2008;59(5):275-281. (Ita).
181 Zingg PO, Jost B, Sukthankar A, et al. Clinical and structural outcomes of nonoperative management of massive rotator cuff tears. J Bone Joint Surg Am. Sep. 2007;89(9):1928-1934. [pmid: 17768188].
182 Zvijac JE, Levy HJ, Lemak LJ. Arthroscopic subacromial decompression in the treatment of full thickness rotator cuff tears: a 3- to 6-year follow-up. Arthroscopy. Oct. 1994;10(5):518-523. [pmid: 7999159].

## Excluded – Not Population of Interest (N = 15)

The following studies were excluded because they failed to meet our population inclusion criteria.

1 Brooks A, Domb B, ElAttrache N, et al. High-tension double-row footprint repair versus reduced-tension single-row repair in massive rotator cuff tears. J Investig Med. 2008;56(1):209.
2 Deutsch A. Arthroscopic rotator cuff repair: The effect of depth of suture passage on three-dimensional repair site surface area and load to failure using single-row anchor fixation. J Shoulder Elbow Surg. 16(2):e41. [pmid: 17629509].
3 Domb BG, Gloustrian RE, Brooks A, et al. High-tension double-row footprint repair compared with reduced-tension single-row repair for massive rotator cuff tears. J Bone Joint Surg Am. 2008;90(Suppl 4):35-39. [pmid: 18984716].
4 Ecklund KJ, Chu EH, McGarry MH, et al. Reverse Shoulder Arthroplasty Restores Abductor Muscle Efficiency in Massive Rotator Cuff Tears. Journal of the American Academy of Orthopaedic Surgeons. 2007;15(6):340-349. [pmid: 17548883].
5 Jia XL, Fan RF, Li HQ, et al. Diagnosis and treatment of traumatic subscapularis tendon ruptur. Zhongguo Gu Shang. 2009;22(2):118-119. [pmid: 19281021].
6 Koh JL, Szomor Z, Murrell GA, et al. Supplementation of rotator cuff repair with a bioresorbable scaffold. Am J Sports Med. May. 2002;30(3):410. [pmid: 12016083].
7 Lopez-Vidriero E, Costic R, Lara J, et al. Biomechanical properties of different placement of achors for rotator cuff repair. 53rd Annual Meeting of the Orthopaedic Research Society. San Diego, CA. Feb 11–14, 2007.
8 Magermans DJ, Chadwick EKJ, Veeger HEJ, et al. Biomechanical analysis of tendon transfers for massive rotator cuff tears. Clin Biomech. 2004;19(4):350-357.
9 Manigrasso MB, Meier SW. Rotator Cuff Repair: The effect of dual-row fixation on tendon-bone motion at the repair interface. 52nd Annual Meeting of the Orthopaedic Research Society. Chicago, IL. Mar 19–22, 2006.
10 Meier SW, Meier JD, Levy AS. Rotator cuff repair: The effect of double-row fixation vs. single-row fixation on three-dimensional repair site. Arthroscopy Association of North America 23rd Annual Meeting. Orlando, FL. Apr 22–25, 2004.
11 Min K, Siskosky M, Lee T. Transosseous equivalent arthroscopic rotator cuff repair using push lock versus conventional double-row fixation. J Investig Med. 2007;55(1 Suppl S):S134.
12 Park MC, Pirolo JM, Park CJ, et al. The effect of abduction and rotation on footprint contact for single-row, double-row, and modified double-row rotator cuff repair techniques. Am J Sports Med. 2009;37(8):1599-1608. [pmid: 19417121].
13 Park MC, Pirolo JM, Park CJ, et al. The effect of internal and external rotation on footprint contact comparing double-row and transosseous-equivalent rotator cuff repair techniques. 54th Annual Meeting of the Orthopaedic Research Society. San Francisco, CA. Mar 2–5, 2008.
14 Steenbrink F, de Groot JH, Veeger HE, et al. Glenohumeral stability in simulated rotator cuff tears. J Biomech. 2009;42(11):1740-1745. [pmid: 19450803].
15 Tamborlane J, Oka R, Mahar A, Pedowitz R. Strength of double row arthroscopic rotator cuff repair. 52nd Annual Meeting of the Orthopaedic Research Society. Chicago, IL. Mar 19–22, 2006.

## Excluded – Not Confirmed Rotator Cuff Tear (N = 107)

The following studies were excluded because RC tears were not confirmed using diagnostic imaging or intraoperative findings.

1 Abboud JA, Silverberg D, Pepe M, et al. Surgical treatment of os acromiale with and without associated rotator cuff tears. J Shoulder Elbow Surg. May. 2006;15(3):265-270. [pmid: 16679224].
2 Adamietz B, Sauer R, Keilholz L. Bestrahlung beim impingementsyndrom des schultergelenks [Radiotherapy for shoulder impingement]. Strahlenther Onkol. May. 2008;184(5):245-250. (Ger). [pmid: 18427754].
3 Adebajo AO, Nash P, Hazleman BL. A prospective double blind dummy placebo controlled study comparing triamcinolone hexacetonide injection with oral diclofenac 50 mg TDS in patients with rotator cuff tendinitis. J Rheumatol. Sep. 1990;17(9):1207-1210. [pmid: 2290163].
4 Adolfsson L, Lysholm J. Results of arthroscopic acromioplasty related to rotator cuff lesions. Int Orthop. 1993;17(4):228-231. [pmid: 8407038].
5 Akpinar S, Hersekli MA, Ozalay M, et al. [Arthroscopic acromioplasty in the treatment of subacromial impingement syndrome]. Artroplasti Artroskopik Cerrahi. 2003;14(2):94-97.
6 Alfredson H, Harstad H, Haugen S, et al. Sclerosing polidocanol injections to treat chronic painful shoulder impingement syndrome: results of a two-centre collaborative pilot study. Knee Surg Sports Traumatol Arthrosc. 2006;14(12):1321-1326. [pmid: 17028867].
7 Alvarez CM, Litchfield R, Jackowski D, et al. A prospective, double-blind, randomized clinical trial comparing subacromial injection of betamethasone and xylocaine to xylocaine alone in chronic rotator cuff tendinosis. Am J Sports Med. 2005;33(2):255-262. [pmid: 15701612].
8 Andersen NH, Sojbjerg JO, Johannsen HV, et al. Self-training versus physiotherapist-supervised rehabilitation of the shoulder in patients treated with arthroscopic subacromial decompression: a clinical randomized study. J Shoulder Elbow Surg. Mar. 1999;8(2):99-101. [pmid: 10226959].
9 Baltaci G, Bayrakci TV, Binnet M, et al. Rehabilitation in arthroscopic subacromial decompression: six-year follow-up. Fizyoterapi Rehabilitasyon. 2007;18(3):201-208.
10 Bartolozzi A, Andreychik D, Ahmad S. Determinants of outcome in the treatment of rotator cuff disease. Clin Orthop Relat Res. Nov. 1994;(308):90-97.
11 Bengtsson M, Lunsjo K, Hermodsson Y, et al. High patient satisfaction after arthroscopic subacromial decompression for shoulder impingement: a prospective study of 50 patients. Acta Orthop. Feb. 2006;77(1):138-142. [pmid: 16534714].
12 Bennell K, Coburn S, Wee E, et al. Efficacy and cost-effectiveness of a physiotherapy program for chronic rotator cuff pathology: a protocol for a randomised, double-blind, placebo-controlled trial. BMC Musculoskelet Disord. 2007;8:86. [pmid: 17761004].
13 Bezer M, Aydin N, Erol B, et al. Artroskopik ve acik anterior akromiyoplasti: gec donem sonuclar [Late results of arthroscopic and open anterior acromioplasty]. Acta Orthop Traumatol Turc. 2004;38(2):115-119. (Tur). [pmid: 15129029].
14 Bingol U, Altan L, Yurtkuran M. Low-power laser treatment for shoulder pain. Photomed Laser Surg. 2005;23(5):459-464. [pmid: 16262574].
15 Blaine T, Moskowitz R, Udell J, et al. Treatment of persistent shoulder pain with sodium hyaluronate: a randomized, controlled trial. A multicenter study. J Bone Joint Surg Am. May. 2008;90(5):970-979. [pmid: 18451387].
16 Boileau P. Arthroscopic bristow procedure for anterior instability in shoulders with a stretched or deficient capsule: the “belt-and-suspenders” operative technique and preliminary results. Arthroscopy. 2007;23(6):593-601. [pmid: 17560473].
17 Boileau P, Parratte S, Chuinard C, et al. Arthroscopic treatment of isolated type II SLAP lesions: biceps tenodesis as an alternative to reinsertion. Am J Sports Med. 2009;37(5):929-936. [pmid: 19229046].
18 Brox JI, Staff PH, Ljunggren AE, et al. Arthroscopic surgery compared with supervised exercises in patients with rotator cuff disease (stage II impingement syndrome)[erratum appears in BMJ 1993 Nov 13;307(6914):1269]. Br Med J. Oct. 9. 1993;307(6909):899-903. [pmid: 8241852].
19 Budoff JE, Nirschl RP, Guidi EJ. Debridement of partial-thickness tears of the rotator cuff without acromioplasty: long-term follow-up and review of the literature. [Review] [58 refs]. J Bone Joint Surg Am. May. 1998;80(5):733-748. [pmid: 9611036].
20 Burns TP, Turba JE. Arthroscopic treatment of shoulder impingement in athletes. Am J Sports Med. 1992;20(1):13-16. [pmid: 1554066].
21 Cabot A, Cabot JC. Minimal incision acromioplasty. Orthopedics. 2002;25(12):1347-1350. [pmid: 12502196].
22 Carreira DS, Mazzocca A. A prospective outcome evaluation of arthroscopic bankart repairs : minimum 2-year follow-up. Am J Sports Med. 2006;34(5):771-777. [pmid: 16627629].
23 Cheng AS, Hung LK. Randomized controlled trial of workplace-based rehabilitation for work-related rotator cuff disorder. J Occup Rehabil. Sep. 2007;17(3):487-503. [pmid: 17520356].
24 Dayican A, Ozturk C, Portakal S, et al. [The results of anterior acromioplasty for the treatment of the impingement syndrome in the shoulder]. Artroplasti Artroskopik Cerrahi. 2002;13(2):73-77. (Tur).
25 Di Fabio RP, Boissonnault W. Physical therapy and health-related outcomes for patients with common orthopaedic diagnoses. J Orthop Sports Phys Ther. Mar. 1998;27(3):219-230. [pmid: 9513868].
26 Di Lorenzo L, Pappagallo M, Gimigliano R, et al. Pain relief in early rehabilitation of rotator cuff tendinitis: any role for indirect suprascapular nerve block?. Eura Medicophys. Sep. 2006;42(3):195-204. [pmid: 17039215].
27 Dickens VA, Williams JL, Bhamra MS. Role of physiotherapy in the treatment of subacromial impingement syndrome: a prospective study. Physiotherapy. 2005;91(3):159-164.
28 Doneux PS, Miyazaki AN, Pinheiro JA Jr, et al. Incidencia de dor acromioclavicular apos descompressao subacromial artroscopica [Incidence of acromioclavicular pain after arthroscopic subacromial decompression]. Rev Bras Ortop. 1998;33(5):329-332. (Por).
29 Doneux PS, Miyazaki AN, Pinheiro JA Jr, et al. Tratamento da sindrome do impacto em tenistas [Treatment of impingement syndrome in tennis players]. Rev Bras Ortop. 1998;33(12):939-944. (Por).
30 Ellman H, Kay SP. Arthroscopic subacromial decompression for chronic impingement: two- to five-year results. J Bone Joint Surg Br. May. 1991;73(3):395-398. [pmid: 1670435].
31 Ferreiro Marzoa I, Veiga Suarez M, Guerra Pena JL, et al. Rehabilitating treatment of painful shoulder. Rehabil. 2005;39(3):113-120.
32 Frieman BG, Fenlin JM Jr. Anterior acromioplasty: effect of litigation and workers’ compensation. J Shoulder Elbow Surg. May. 1995;4(3):175-181. [pmid: 7552674].
33 Friis J, Jarner D, Toft B, et al. Comparison of two ibuprofen formulations in the treatment of shoulder tendonitis. Clin Rheumatol. Mar. 1992;11(1):105-108. [pmid: 1582107].
34 Garcia Diaz MF, Medina SM. Evolucion y caracteristicas de los pacientes con hombro doloroso en atencion primaria [Evolution and characteristics of primary care patients with painful shoulder]. Aten Primaria. 2005;35(4):192-197. (Spa). [pmid: 15766494].
35 Garmann S, Dilmac N, Marquardt B, et al. Endergebnis nach operativer behandlung von schultergelenksinfekten [Final results after operative treatment of shoulder joint infections]. Z Orthop Ihre Grenzgeb. Nov. 2003;141(6):643-649. (Ger). [pmid: 14679429].
36 Genc A, Ozcan A, Gelecek N. Evre II Rotator Manset Yaylanmalarinin Teadavysynde Pyroksykam Fonoforez Uygulamasinin Etkynlydy [The effectiveness of piroxicam phonophoresis for treatment of stage II rotator cuff injuries]. Artroplasti Artroskopik Cerrahi. 2002;13(1):23-26. (Tur).
37 Ginsberg F, Famaey JP. Double-blind, randomized crossover study of the percutaneous efficacy and tolerability of a topical indomethacin spray versus placebo in the treatment of tendinitis. J Int Med Res. Mar. 1991;19(2):131-136. [pmid: 1864449].
38 Giombini A, Di CA, Safran MR, et al. Short-term effectiveness of hyperthermia for supraspinatus tendinopathy in athletes: a short-term randomized controlled study. Am J Sports Med. Aug. 2006;34(8):1247-1253. [pmid: 16636345].
39 Godges JJ, Mattson-Bell M, Thorpe D, et al. The immediate effects of soft tissue mobilization with proprioceptive neuromuscular facilitation on glenohumeral external rotation and overhead reach. J Orthop Sports Phys Ther. 2003;33(12):713-718. [pmid: 14743984].
40 Gosse F, Ruhmann O, Wirth CJ. Arthrodesis of the glenohumeral joint using a 4.5-mm reconstruction plate. Oper Orthop Traumatol. 2003;15(2):170-187. (Ger, Eng).
41 Greve JM, Rossi JD, Cossermelli W, et al. Reabilitacao funcional das lesoes tendinosas degenerativas do ombro [Functional rehabilitation of degenerative tendinous injuries of the shoulder]. Rev Hosp Clin Fac Med Sao Paulo. Mar. 1991;46(2):78-81. (Spa). [pmid: 1843372].
42 Grymel-Kulesza E, Polak A. Wplyw kompleksowej terapii obejmujacej cwiczenia czynne, masaz[dot] klasyczny, krioterapie oraz laczne dzialanie ultradzwiekow i pradu elektrycznego w leczeniu uszkodzen pierscienia rotatorow [The effect of a multimodality therapy including active exercises, classic massage, cryotherapy and a combination of ultrasound and electrical stimulation on rotator cuff injuries]. Fizjoterapia Polska. 2007;7(2):107-123. (Pol).
43 Haahr JP, Andersen JH. Exercises may be as efficient as subacromial decompression in patients with subacromial stage II impingement: 4–8-years’ follow-up in a prospective, randomized study. Scand J Rheumatol. 2006;35(3):224-8. [pmid: 16766370].
44 Hartwig CH, Burkhard R. Operative release of the impingement syndrome. Indication, technique, results. Arch Orthop Trauma Surg. 1996;115(5):249-254. [pmid: 8836456].
45 Hsieh KH, Lee PY, Lee TS, et al. Functional assessment for shoulder impingement syndrome after anterior acromioplasty. Chin Med J. Jun. 1997;59(6):354-358.
46 Huang G, Xue Q, Sun C. [Impingement syndrome of the subacromial area: analysis of 42 cases]. Zhonghua Wai Ke Za Zhi. Jan. 1997;35(1):35-37. (Chi). [pmid: 10374506].
47 Hyvonen P, Lohi S, Jalovaara P. Open acromioplasty does not prevent the progression of an impingement syndrome to a tear. Nine-year follow-up of 96 cases. J Bone Joint Surg Br. Sep. 1998;80(5):813-816. [pmid: 9768891].
48 Imhoff A, Ledermann T. Arthroscopic subacromial decompression with and without the Holmium:YAG-laser: a prospective comparative study. Arthroscopy. Oct. 1995;11(5):549-556. [pmid: 8534295].
49 Innocenti M, Muncibi F, Coppacchioli D, et al. Arthroscopic treatment of non-calcific rotator cuff tendinitis. Journal of Sports Traumatology and Related Research. 1999;21(3):140-144.
50 Itzkowitch D, Ginsberg F, Leon M, et al. Peri-articular injection of tenoxicam for painful shoulders: a double-blind, placebo controlled trial. Clin Rheumatol. Nov. 1996;15(6):604-609. [pmid: 8973872].
51 Jerosch J, Strauss JM, Schneider T. Die arthroskopische subacromiale dekompression: 1–3 Jahresergebnisse. [Arthroscopic subacromial decompression: 1–3 year results]. Z Orthop Ihre Grenzgeb. Sep. 1992;130(5):406-412. (Ger). [pmid: 1462701].
52 Jully JL, Scheffer JC, Katz D. Coiffes non operees. Kinesither Sci. 1995:7-10. (Fre).
53 Katz DV. Luxations et fractures luxations inveterees de l’ epaule traitees par arthroplastie: a propos de 14 cas. Ann Orthop Ouest. 2005:93-96. (Fre).
54 Kleinhenz J, Streitberger K, Windeler J, et al. Randomised clinical trial comparing the effects of acupuncture and a newly designed placebo needle in rotator cuff tendinitis. Pain. Nov. 1999;83(2):235-241. [pmid: 10534595].
55 Lathia AT, Jung SM, Chen LX. Efficacy of acupuncture as a treatment for chronic shoulder pain. J Altern Complement Med. 2009;15(6):613-618. [pmid: 19489707].
56 Lewis JS, Wright C, Green A. Subacromial impingement syndrome: the effect of changing posture on shoulder range of movement. J Orthop Sports Phys Ther. 2005;35(2):72-87. [pmid: 15773565].
57 Lill H, Korner J, Hepp P, et al. Age-dependent prognosis following conservative treatment of traumatic anterior shoulder dislocation. Eur J Trauma. 2001;27(1):29-33.
58 MacDermid JC, Ramos J, Drosdowech D, et al. The impact of rotator cuff pathology on isometric and isokinetic strength, function, and quality of life. J Shoulder Elbow Surg. 2004;13(6):593-598. [pmid: 15570226].
59 Marc T. Societe francaise des masseurs kinesitherapeutes du sport SFMKS Fp. Protocole et resultats de la reeducation des tendinopathies de la coiffe des rotateurs: sport, sante et prevention. Kinesither Sci. 2003:25-30. (Fre).
60 Mayerhoefer ME, Breitenseher MJ, Wurnig C, et al. Shoulder impingement: relationship of clinical symptoms and imaging criteria. Clin J Sport Med. 2009;19(2):83-89. [pmid: 19451760].
61 Mole D, Kempf JF, Gleyze P, et al. Resultats du traitement arthroscipique des tendinopathies non rompues de la coiffe des rotateurs. 2e partie: les calcifications de la coiffe des rotateurs [Results of endoscopic treatment of non-broken tendinopathies of the rotator cuff. 2: calcifications of the rotator cuff]. Rev Chir Orthop Reparatrice Appar Mot. 1993;79(7):532-541. (Fre). [pmid: 8085035].
62 Morrison DS, Frogameni AD, Woodworth P. Nonoperative treatment of subacromial impingement syndrome. J Bone Joint Surg Am. May. 1997;79(5):732-737. [pmid: 9160946].
63 Naredo E, Cabero F, Beneyto P, et al. A randomized comparative study of short term response to blind injection versus sonographic-guided injection of local corticosteroids in patients with painful shoulder. J Rheumatol. 2004;31(2):308-314. [pmid: 14760802].
64 Nicoletti SJ, Carrera EF, Neto NA, et al. Tratamento artroscopico da sindrome do pincamento subacromial, come e sem acromioplastia: resultados apos seguimento medio de 45 meses [Arthroscopic subacromial bursectomy with and without acromioplasty for treatment of impingement syndrome: functional results after a 45 month follow-up]. Rev Bras Ortop. 1998;33(5):333-337. (Por).
65 Nobuhara K, Sugiyama D, Ikeda H, et al. Contracture of the shoulder. Clin Orthop Relat Res. May. 1990;(254):105-110.
66 Odenbring S, Wagner P, Atroshi I. Long-term outcomes of arthroscopic acromioplasty for chronic shoulder impingement syndrome: a prospective cohort study with a minimum of 12 years’ follow-up. Arthroscopy. 2008;24(10):1092-1098. [pmid: 19028159].
67 Ogilvie-Harris DJ, Boynton E. Arthroscopic acromioplasty: extravasation of fluid into the deltoid muscle. Arthroscopy. 1990;6(1):52-54. [pmid: 2310452].
68 Pagan Conesa JA, Mas MJ, Sanchez MA, et al. Analisis prospectivo de una serie de artroscopias de hombro en el tratamiento de la patologia del manguito rotador. [Prospective analysis of a series of shoulder arthroscopies in the treatment of rotator cuff tears]. Rev Ortop Traumatol. 2003;47(1):16-25. (Spa).
69 Paoloni JA, Appleyard RC, Nelson J, et al. Topical glyceryl trinitrate application in the treatment of chronic supraspinatus tendinopathy: a randomized, double-blinded, placebo-controlled clinical trial. Am J Sports Med. Jun. 2005;33(6):806-813. [pmid: 15827365].
70 Patel VR, Singh D, Calvert PT, et al. Arthroscopic subacromial decompression: results and factors affecting outcome. J Shoulder Elbow Surg. May. 1999;8(3):231-237. [pmid: 10389078].
71 Paulos LE, Franklin JL. Arthroscopic shoulder decompression development and application: a five year experience. Am J Sports Med. May. 1990;18(3):235-244. [pmid: 2372071].
72 Pigozzi F, Giombini A, Parisi A, et al. The application of shock-waves therapy in the treatment of resistant chronic painful shoulder: a clinical experience. J Sports Med Phys Fitness. Dec. 2000;40(4):356-361. [pmid: 11297007].
73 Pogliaghi S, Malgrati D. A new taping technique for shoulder impingement. Eura Medicophys. 1998;34(3):137-144.
74 Rabin SI, Post M. A comparative study of clinical muscle testing and Cybex evaluation after shoulder operations. Clin Orthop Relat Res. Sep. 1990;(258):147-156.
75 Rahme H, Solem-Bertoft E, Westerberg CE, et al. The subacromial impingement syndrome: a study of results of treatment with special emphasis on predictive factors and pain-generating mechanisms. Scand J Rehabil Med. Dec. 1998;30(4):253-262. [pmid: 9825390].
76 Rao SE, Muzammil S, Hobbs NJ. Subacromial decompression for shoulder impingement syndrome. J Coll Physicians Surg Pak. Mar. 2006;16(3):208-211. [pmid: 16542602].
77 Razmjou H, Holtby R, Myhr T. Gender differences in quality of life and extent of rotator cuff pathology. Arthroscopy. 2006;22(1):57-62. [pmid: 16399462].
78 Rockwood CA Jr, Williams GR Jr, Burkhead WZ Jr. Debridement of degenerative, irreparable lesions of the rotator cuff. J Bone Joint Surg Am. Jun. 1995;77(6):857-866. [pmid: 7782358].
79 Russell AL. Piroxicam 0.5% topical gel compared to placebo in the treatment of acute soft tissue injuries: a double-blind study comparing efficacy and safety. Clin Invest Med. Feb. 1991;14(1):35-43. [pmid: 2040104].
80 Saab M, Randall PE. Treatment of acute supraspinatus tendinitis: physiotherapy or steroid injection?. Eur J Emerg Med. Sep. 1997;4(3):176. [pmid: 9427003].
81 Sachs RA, Stone ML, Devine S. Open vs. arthroscopic acromioplasty: a prospective, randomized study. Arthroscopy. Jun. 1994;10(3):248-254. [pmid: 8086015].
82 San Segundo RM, Valdes JM, Fernandez TR. Conservative treatment in shoulder pain: ultrasounds respect sham insonation: a clinical trial. Rehabil. 2008;42(2):61-66.
83 Schneider T, Strauss JM, Hoffstetter I, et al. Shoulder joint stability after arthroscopic subacromial decompression. Arch Orthop Trauma Surg. 1994;113(3):129-133. [pmid: 8054232].
84 Schneider T, Straus JM, Fink B, et al. Influence de la stabilite articulaire sur les resultats de la decompression sous-acromiale par voie arthroscopique. Acta Orthop Belg. 1996;62(2):94-99. [pmid: 8767158].
85 Schroder JV. Open versus arthroscopic treatment of chronic rotator cuff impingement. Arch Orthop Trauma Surg. 2001;121(5):241-244. [pmid: 11409550].
86 Shi Y. Experience of comprehensive rehabilitation treatment on 60 cases of muscle strain at neck and shoulder. Chin J Clin Rehab. 2003;7(2):313.
87 Smith AM, Mardones RM, Sperling JW, et al. Early complications of operatively treated proximal humeral fractures. J Shoulder Elbow Surg. 2007;16(1):14-24. [pmid: 17113321].
88 Sonnabend DH. Treatment of primary anterior shoulder dislocation in patients older than 40 years of age: conservative versus operative. Clin Orthop Relat Res. Jul. 1994;(304):74-77.
89 Spangehl MJ, Hawkins RH, McCormack RG, et al. Arthroscopic versus open acromioplasty: a prospective, randomized, blinded study. J Shoulder Elbow Surg. Mar. 2002;11(2):101-107. [pmid: 11988719].
90 Speer KP, Lohnes J, Garrett WE Jr. Arthroscopic subacromial decompression: results in advanced impingement syndrome. Arthroscopy. 1991;7(3):291-296. [pmid: 1750939].
91 Stephens SR, Warren RF, Payne LZ, et al. Arthroscopic acromioplasty: a 6- to 10-year follow-up. Arthroscopy. May. 1998;14(4):382-388. [pmid: 9620649].
92 Strobel G. Therapeutischelangzeitwirkung unterschiedlicher intraartikularer injektionsbehandlung der schmerzhaften schulter: auswirkung auf Schmerz, Beweglichkeit und Arbeitsfahigkeit [Long-term therapeutic effect of different intra-articular injection treatments of the painful shoulder: effect on pain, mobility and work capacity]. Rehabilitation (Stuttg). Aug. 1996;35(3):176-178. (Ger). [pmid: 8975347].
93 Stuart MJ, Azevedo AJ, Cofield RH. Anterior acromioplasty for treatment of the shoulder impingement syndrome. Clin Orthop Relat Res. Nov. 1990;(260):195-200.
94 Tasto JP, Cummings J, Medlock V, et al. The tendon treatment center: new horizons in the treatment of tendinosis. Arthroscopy. Dec. 2003;19(Suppl 1):213-223. [pmid: 14673441].
95 Thelen MD, Dauber JA, Stoneman PD. The clinical efficacy of Kinesio Tape for shoulder pain: a randomized, double-blinded, clinical trial. J Orthop Sports Phys Ther. 2008;38(7):389-395. [pmid: 18591761].
96 Thomas M, Grunert J, Standtke S, et al. Seilzugisokinetik in der schulterrehabilitation: erste ergebnisse. [Isokinetic pulley-system in shoulder rehabilitation: first results]. Z Orthop Ihre Grenzgeb. 2001;139(1):80-86. (Ger). [pmid: 11253528].
97 Van Holsbeeck E, DeRycke J, Declercq G, et al. Subacromial impingement: open versus arthroscopic decompression. Arthroscopy. 1992;8(2):173-178. [pmid: 1637428].
98 Vecchio P, Cave M, King V, et al. A double-blind study of the effectiveness of low level laser treatment of rotator cuff tendinitis. Br J Rheumatol. Aug. 1993;32(8):740-742. [pmid: 8348278].
99 Vecchio PC, Hazleman BL, King RH. A double-blind trial comparing subacromial methylprednisolone and lignocaine in acute rotator cuff tendinitis. Br J Rheumatol. Aug. 1993;32(8):743-745. [pmid: 8348279].
100 Volpon JB, Muniz AAS. Resultado do tratamento cirurgico do pincamento do manguito rotador do ombro pela descompressao subacromial [Results of the surgical treatment of the shoulder rotator cuff impingement by subacromial decompression]. Rev Bras Ortop. 1997;32(1):65-69. (Por).
101 Watson J, Helliwell P, Morton V, et al. Shoulder acute pain in primary healthcare: is retraining effective for GP principals? SAPPHIRE: a randomized controlled trial. Rheumatology. 2008;47(12):1795-1802. [pmid: 18820310].
102 Wiley P. Low-energy extracorporeal shock-wave treatment for tendinitis of the supraspinatus. Clin J Sport Med. 2002;12(4):262. [pmid: 12150161].
103 Wittenberg RH, Rubenthaler F, Wolk T, et al. Surgical or conservative treatment for chronic rotator cuff calcifying tendinitis: a matched-pair analysis of 100 patients. Arch Orthop Trauma Surg. 2001;121(1–2):56-59. [pmid: 11195119].
104 Wright RW, Heller MA, Quick DC, et al. Arthroscopic decompression for impingement syndrome secondary to an unstable os acromiale. Arthroscopy. Sep. 2000;16(6):595-599. [pmid: 10976119].
105 Yamaguchi K, Buchbinder R, Green S, et al. Arthrographic distension with saline and steroid reduced pain and disability and improved range of motion in the short term in patients with painful stiff shoulder. J Bone Joint Surg Am. 2004;86(8):1837.
106 Yu CM, Chen CH, Liu HT, et al. Subacromial injections of corticosteroids and xylocaine for painful subacromial impingement syndrome. Chang Gung Med J. Sep. 2006;29(5):474-479. [pmid: 17214391].
107 Zuinen C. Diclofenac/misoprostol vs diclofenac/placebo in treating acute episodes of tendinitis/bursitis of the shoulder. Drugs. 1993;45(Suppl 1):17-23. [pmid: 7685684].

## Excluded – Primary Intention Was Not Treatment of RC Tears (N = 59)

The following studies were excluded because their primary intention was not the treatment of RC tears.

1 Allom R, Colegate-Stone T, Gee M, et al. Outcome analysis of surgery for disorders of the rotator cuff: a comparison of subjective and objective scoring tools. J Bone Joint Surg Br. 2009;91(3):367-373. [pmid: 19258614].
2 Arcand MA, O’Rourke P, Zeman CA, et al. Revision surgery after failed subacromial decompression. Int Orthop. 2000;24(2):61-64. [pmid: 10894371].
3 Arntz CT, Matsen FA III, Jackins S. Surgical management of complex irreparable rotator cuff deficiency. J Arthroplasty. Dec. 1991;6(4):363-370. [pmid: 1770374].
4 Barbier C, Caillat-Miousse JL. Etude radiologique preliminaire de l’ influence de “ l’ abaissement actif “ de la tete humerale, sur la variation de l’ espace sous-acromial: la recherche en Kinesitherapie. Ann Kinésithér. 2000;27(1):12-20. (Fre).
5 Baumann B, Genning K, Bohm D, et al. Arthroscopic prevalence of pulley lesions in 1007 consecutive patients. J Shoulder Elbow Surg. Jan. 2008;17(1):14-20. [pmid: 17931909].
6 Bigliani LU, Cordasco FA, McIlveen SJ, et al. Operative treatment of failed repairs of the rotator cuff. J Bone Joint Surg Am. Dec. 1992;74(10):1505-1515. [pmid: 1469010].
7 Blauth W, Gartner J. Ergebnisse postoperativer arthrographien nach Naht rupturierter rotatorenmanschetten [Postoperative results of arthrography following suturing of ruptured rotator cuff]. Orthopade. Sep. 1991;20(4):262-265. (Ger). [pmid: 1945403].
8 Boileau P, Krishnan SG, Coste JS, et al. Arthroscopic biceps tenodesis: a new technique using bioabsorbable interference screw fixation. Arthroscopy. Nov. 2002;18(9):1002-1012. [pmid: 12426544].
9 Braune C, Gramlich H. Der makroskopische aspekt der rotatorenmanschettenruptur bei traumatischen und atraumatischen rupturformen. Unfallchirurg. 2000;103(6):462-467. (Ger). [pmid: 10925648].
10 Burkhead J, Schiffern SC, Krishnan SG. Use of Graft Jacket as an augmentation for massive rotator cuff tears. Semin Arthroplasty. 2007;18(1):11-18.
11 Camos P, Ceriani A, Gnemmi GC, et al. Il conflitto subacromiale [Shoulder impingement syndrome]. Minerva Ortop Traumatol. 1996;47(12):677-681. (Ita).
12 Chen AL, Shapiro JA, Ahn AK, et al. Rotator cuff repair in patients with type I diabetes mellitus. J Shoulder Elbow Surg. Sep. 2003;12(5):416-421. [pmid: 14564259].
13 Chui CH, Lee C, Seow KH. The results of open acromioplasty in impingement syndrome—a retrospective study. Singapore Med J. Jan. 1997;38(1):22-24. [pmid: 9269349].
14 Cummins CA, Murrell GA. Mode of failure for rotator cuff repair with suture anchors identified at revision surgery. J Shoulder Elbow Surg. Mar. 2003;12(2):128-133. [pmid: 12700563].
15 Della Sala SW, Bianchini G. La risonanza Magnetica nello studio della spalla dolorosa: raffronto chirugico in 30 casi consecutive [Magnetic resonance in the study of the painful shoulder: the surgical comparison in 30 consecutive cases]. Radiol Med. Apr. 1996;91(4):348-355. (Ita). [pmid: 8643842].
16 Djurasovic M, Marra G, Arroyo JS, et al. Revision rotator cuff repair: factors influencing results. J Bone Joint Surg Am. Dec. 2001;83(12):1849-1855. [pmid: 11741065].
17 Ekeberg OM, Bautz-Holter E, Tveita EK, et al. Subacromial ultrasound guided or systemic steroid injection for rotator cuff disease: randomised double blind study. BMJ. 2009;338:3112.
18 Epstein B, Childers MK. The use of gabapentin for neuropathic and musculoskeletal pain: a case series. J Neurol Rehabil. 1998;12(2):81-86.
19 Field LD, Warren RF, O’Brien SJ, et al. Isolated closure of rotator interval defects for shoulder instability. Am J Sports Med. 1995;23(5):557-563. [pmid: 8526270].
20 Flurin PH. Ruptures traumatiques de la coiffe des rotateurs chez le rugbyman. J Traumatol Sport. 2007;24(4):203-206.
21 Fornara P, Caniggia M, Ceffa R, et al. Studio preoperatorio con proiezione radiografica “outlet-view” in 150 pazienti operati per sindrome da conflitto sub-acromiale[Preoperative study with “outlet-view” radiographic projection in 150 patients undergoing shoulder impingement syndrome surgery]. Minerva Ortop Traumatol. 2001;52(6):245-249. (Ita).
22 Fuchs S, Langenbrick A. Haufigkeit, symptomatik und relevanz von klinisch manifesten rotatorenmanschettenlasionen im alter. Aktuelle Traumatol. 1999;29(1):1-7. (Ger).
23 Gradl G, Dietze A, Arndt D, et al. Angular and sliding stable antegrade nailing (Targon PH) for the treatment of proximal humeral fractures. Arch Orthop Trauma Surg. 2007;127(10):937-944. [pmid: 17901964].
24 Hamada K, Fukuda H, Mikasa M, et al. Roentgenographic findings in massive rotator cuff tears: a long-term observation. Clin Orthop Relat Res. May. 1990;(254):92-96.
25 Hartsell HD, Forwell L. Postoperative eccentric and concentric isokinetic strength for the shoulder rotators in the scapular and neutral planes. J Orthop Sports Phys Ther. Jan. 1997;25(1):19-25. [pmid: 8979172].
26 Hattrup SJ, Cofield RH, Cha SS. Rotator cuff repair after shoulder replacement. J Shoulder Elbow Surg. Jan. 2006;15(1):78-83. [pmid: 16414473].
27 Hiemstra LA, Sasyniuk TM, Mohtadi NG, et al. Shoulder strength after open versus arthroscopic stabilization. Am J Sports Med. 2008;36(5):861-867. [pmid: 18319347].
28 Jacquot N. Le long biceps peut-il etre sain dans les ruptures de la coiffe des rotateurs? Epidemiologie et comportement dynamique. Rev Chir Orthop Reparatrice Appar Mot. S30. 2007;93(8):5-5S. 31. (Fre). [pmid: 17389819].
29 Jerosch J, Schroder M, Schneider T. Arthroscopic resection of the acromioclavicular joint: indications, surgical technique, outcome. Unfallchirurg. Sep. 1998;101(9):691-696. (Ger). [pmid: 9816978].
30 Joo HO, Sae HK, Ho KL, et al. Trans-rotator cuff portal is safe for arthroscopic superior labral anterior and posterior lesion repair: clinical and radiological analysis of 58 SLAP lesions. Am J Sports Med. 2008;36(10):1913-1921. [pmid: 18495968].
31 Levigne C, Boileau P, Favard L, et al. Scapular notching in reverse shoulder arthroplasty. J Shoulder Elbow Surg. 2008;17(6):925-935. [pmid: 18558499].
32 Lo IKY, Burkhart SS. Arthroscopic revision of failed rotator cuff repairs: technique and results. Arthroscopy. Mar. 2004;20(3):250-267. [pmid: 15007314].
33 Lo IKY, Burkhart SS. Immediate postoperative fluid retention and weight gain after shoulder arthroscopy. Arthroscopy. May. 2005;21(5):605-610. [pmid: 15891729].
34 Ma HL, Hung SC, Wang ST, et al. The reoperation of failed rotator cuff repairs. J Chin Med Assoc. Feb. 2003;66(2):96-102. [pmid: 12716007].
35 Mazoue CG, Andrews JR. Repair of full-thickness rotator cuff tears in professional baseball players. Am J Sports Med. Feb. 2006;34(2):182-189. [pmid: 16260470].
36 McKee MD, Yoo DJ. The effect of surgery for rotator cuff disease on general health status: results of a prospective trial. J Bone Joint Surg Am. Jul. 2000;82(7):970-979. [pmid: 10901312].
37 Mormino MA, Gross RM, McCarthy JA. Captured shoulder: a complication of rotator cuff surgery. Arthroscopy. Aug. 1996;12(4):457-461. [pmid: 8864004].
38 Murrell G, Marshall J, Cummins C. Rotator cuff repair: an evaluation of the mode of failure in rotator cuff repairs identified at revision surgery (n = 21) in 342 consecutive rotator cuff repairs repaired with suture anchors. J Sci Med Sport. 2002;5(4 Suppl):86.
39 Paavolainen P, Ahovuo J. Ultrasonography and arthrography in the diagnosis of tears of the rotator cuff. J Bone Joint Surg Am. Mar. 1994;76(3):335-340. [pmid: 8126038].
40 Park JY, Lee WS, Lee ST. The strength of the rotator cuff before and after subacromial injection of lidocaine. J Shoulder Elbow Surg. Jan. 2008;17(1 Suppl 8):8S-11S. [pmid: 18069014].
41 Pichon H, Startun V, Barthelemy R, et al. Étude comparative de deux techniques de section du tendon du muscle subscapulaire dans l’opération de Latarjet [Comparative study of the anatomic and clinical effect of Weaver or subtotal subscapularis tendon section in Latarjet procedure]. Rev Chir Orthop Reparatrice Appar Mot. Feb. 2008;94(1):12-18. [pmid: 18342025].
42 Post M. Complications of rotator cuff surgery. Clinical orthopaedics and related research. 1990;(254):97-104.
43 Rittmeister M, Kerschbaumer F. Grammont reverse total shoulder arthroplasty in patients with rheumatoid arthritis and nonreconstructible rotator cuff lesions. J Shoulder Elbow Surg. Jan. 2001;10(1):17-22. [pmid: 11182731].
44 Rozing PM. A posterosuperior approach to the shoulder. J Shoulder Elbow Surg. 2008;17(3):431-435. [pmid: 18276167].
45 Savoie FH. Arthroscopic management of posterior instability: evolution of technique and results. Arthroscopy. 2008;24(4):389-396. [pmid: 18375269].
46 Schroder RJ, Scheibel M, Tsynman A, et al. Magnetresonanztomographische Untersuchung des Musculus subscapularis nach offener vorderer Schulterstabilisierung [Magnetic resonance analysis of the subscapularis muscle after open anterior shoulder stabilization]. Rofo. Jul. 2006;178(7):706-712. (Ger). [pmid: 16810630].
47 Scibek JS, Mell A, Downie B, Carpenter J, et al. Shoulder kinematics in patients with full thickness rotator cuff tears following a subacromial injection. University of Michigan. 2005.
48 Seltzer DG, Zvijac J. The technique of arthroscopy-assisted rotator cuff repair. Tech Orthop. 1993;8(3):212-224.
49 Skoff HD. Conservative open acromioplasty. J Bone Joint Surg Br. Nov. 1995;77(6):933-936. [pmid: 7593110].
50 Sonnabend DH, Watson EM. Structural factors affecting the outcome of rotator cuff repair. J Shoulder Elbow Surg. May. 2002;11(3):212-218. [pmid: 12070491].
51 Stark JT, Zbreski MG, Kruger MJ. Resistance training volume during rehabilitation predicts functional outcomes in workers’ compensation rotator cuff repair. Faseb J. 2007;21(5):A581.
52 Suder PA, Hougaard K, Frich LH, et al. Intraarticular findings in the chronically painful shoulder: a study of 32 posttraumatic cases. Acta Orthop Scand. 1994;65(3):339-343. [pmid: 8042491].
53 Urvoy P, Boileau G. Confrontation et validation de plusieurs methodes d’ evaluation des resultats apres chirurgie de la coiffe des rotateurs: plaidoyer pour une expression. Rev Chir Orthop Reparatrice Appar Mot. 1991;77(3):171-178. (Fre). [pmid: 1831921].
54 Viola RW, Boatright KC, Smith KL, et al. Do shoulder patients insured by workers’ compensation present with worse self-assessed function and health status?. J Shoulder Elbow Surg. 2000;9(5):368-372. [pmid: 11075318].
55 Walch G, Boulahia A. Le signe du clairon et le “dropping sign” dans les ruptures de la coiffe des rotateurs. J Traumatol Sport. 1999;16(1):50-56. (Fre).
56 Warner JJP, Higgins L, Parsons IM, et al. Diagnosis and treatment of anterosuperior rotator cuff tears. J Shoulder Elbow Surg. Jan. 2001;10(1):37-46. [pmid: 11182734].
57 Wildner M. Lost to follow-up. J Bone Joint Surg Br. 1995;77(4):657. [pmid: 7615617].
58 Yagci B, Manisali M, Yilmaz E, et al. Indirect MR arthrography of the shoulder in detection of rotator cuff ruptures. Eur Radiol. 2001;11(2):258-262. [pmid: 11218024].
59 Yen D. Limitations of isokinetic testing to determine shoulder strength after rotator cuff repair. Iowa Orthop J. 2005;25:141-144. [pmid: 16089087].

## Excluded – Not Intervention of Interest (N = 47)

The following studies were excluded because they did not examine an intervention of interest for this review.

1 Apoil AM. Kinesitherapie apres reparation de la coiffe par lambeau de deltoide. Pathologie musculo-tendineuse du membre superieur: de l’ epaule a la main. Kinesither Sci. 2000:21-23. (Fre).
2 Arntz CT, Jackins S, Matsen FA III. Prosthetic replacement of the shoulder for the treatment of defects in the rotator cuff and the surface of the glenohumeral joint.[erratum appears in J Bone Joint Surg Am 1993 Jul;75(7):1112]. J Bone Joint Surg Am. Apr. 1993;75(4):485-491. [pmid: 8478376].
3 Atalar AC, Demirhan M, Uysal M. Biseps uzun baßÝnÝn subakromiyal sÝkÝßma sendromuna etkisi ve artroskopik yardÝmlÝ tenodezi [The role of the long head of the biceps in subacromial impingement syndrome and arthroscopic assisted tenodesis]. Acta Orthop Traumatol Turc. 2002;36(5):408-412. (Tur). [pmid: 12594347].
4 Augereau B, Bensaida M, Vandenbussche E, et al. Plastie par lambeau de deltoide des ruptures transfixiantes associées des supraspinatus et infraspinatus non réparables par simple suture avec long biceps conservable [Deltoid muscle flap-plasty of associated transfixiant ruptures of supraspinatus and infraspinatus unrepairable by simple suture with preservable long biceps: twenty-nine cases with hindsight for 10 years and a half]. Rev Chir Orthop Reparatrice Appar Mot. S155. 2004;90(5 Suppl):1-1S. 158. (Fre).
5 Birmingham PM, Neviaser RJ. Outcome of latissimus dorsi transfer as a salvage procedure for failed rotator cuff repair with loss of elevation. J Shoulder Elbow Surg. 2008;17(6):871-874. [pmid: 18760633].
6 Boileau P, Walch G, Noel E, et al. Neer shoulder prosthesis: outcome according to the shoulder disease. Rev Rhum Engl Ed. 1994;61(9):537-547.
7 Boussagol B, Pelissier J, Herisson C, et al. Évaluation des pathologies de la coiffe des rotateurs: analyse comparative de quatre scores [Clinical assessment of rotator cuff lesions: comparative analysis of four scales]. Ann Readapt Med Phys. 1996;39(2):79-88. (Fre).
8 Brownlow HC, Smith C, Corner T, et al. Pain and stiffness in partial-thickness rotator cuff tears. Am J Orthop. 2009;38(7):338-340. [pmid: 19714274].
9 Chavez-Lopez MA, Navarro-Soltero LA, Rosas-Cabral A, et al. Methylprednisolone versus triamcinolone in painful shoulder using ultrasound-guided injection. Mod Rheumatol. 2009;19(2):147-150. [pmid: 19023644].
10 Cho NS, Yi JW, Rhee YG. Arthroscopic biceps augmentation for avoiding undue tension in repair of massive rotator cuff tears. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2009;25(2):183-191.
11 Contreras-Dominguez V, Carbonell-Bellolio P. Continuous interscalene block for analgesia following shoulder rotator cuff repair: evaluation of 2 bupivacaine concentrations applied with the same infusion technique. Rev Esp Anestesiol Reanim. 2008;55(10):610-615. [pmid: 19177862].
12 Dierickx C, Vanhoof H. Massive rotator cuff tears treated by a deltoid muscular inlay flap. Acta Orthop Belg. 1994;60(1):94-100. [pmid: 8171993].
13 Donigan JA, Frisella WA, Haase D, et al. Pre-operative and intra-operative factors related to shoulder arthroplasty outcomes. Iowa Orthop J. 2009;29:60-66. [pmid: 19742087].
14 Favard LO. Societe orthopedique de l’-ouest-SOO. Omarthrose excentree: hemi-arthroplastie versus prothese inversee: resultats a moyen terme [Glenohumeral arthritis: hemiarthroplasty versus reverse prostheses: midterm results]. Ann Orthop Ouest. 2003:81-86. (Fre).
15 Fredrickson MJ, Stewart AW. Continuous interscalene analgesia for rotator cuff repair: a retrospective comparison of effectiveness and cost in 205 patients from a multi-provider private practice setting. Anaesth Intensive Care. 2008;36(6):786-791. [pmid: 19115645].
16 Gedouin JE, Katz D, Colmar M, et al. Le lambeau deltoidien dans les ruptures massives de la coiffe des rotateurs [Deltoid muscle flap for massive rotator cuff tears: 41 cases with a mean 7-year (minimum 5 year) follow-up]. Rev Chir Orthop Reparatrice Appar Mot. Jun. 2002;88(4):365-372. (Fre). [pmid: 12124536].
17 Gerber C. Latissimus dorsi transfer for the treatment of irreparable tears of the rotator cuff. Clin Orthop Relat Res. Feb. 1992;(275):152-160.
18 Gerber C, Maquieira G, Espinosa N. Transfert du grand dorsal pour le traitement des ruptures massives de la coiffe des rotateurs: quels facteurs déterminent le résultat final? [Latissimus dorsi tendon transfer for treatment of massive tears of the rotator cuff: which factors determine the final result?]. Rev Chir Orthop Reparatrice Appar Mot. S158. 2004;90(5 Suppl):1-1S. 162. (Fre).
19 Goutallier D, Postel JM, Van DS, et al. Tension-free cuff repairs with excision of macroscopic tendon lesions and muscular advancement: results in a prospective series with limited fatty muscular degeneration. J Shoulder Elbow Surg. Mar. 2006;15(2):164-172. [pmid: 16517358].
20 Grammont PM, Baulot E. Delta shoulder prosthesis for rotator cuff rupture. Orthopedics. 1993;16(1):65-68. [pmid: 8421661].
21 Guven O, Bezer M, Guven Z, et al. Surgical technique and functional results of irreparable cuff tears reconstructed with the long head of the biceps tendon. Bull Hosp Joint Dis. 2001;60(1):13-17.
22 Hadjicostas PT, Soucacos PN, Theissen M, et al. The use of split deltoid-flap in the treatment of massive rotator cuff defects: a retrospective study of 61 patients. Knee Surg Sports Traumatol Arthrosc. 2008;16(9):876-883. [pmid: 18592217].
23 Huguet D, Gruber P. Societe d’-orthopedie-de-l’-Ouest-SOO. Arthroplasties inversees d’ epaule: analyse clinique et radiographique de 17 cas a 31 mois de recul. Les Sables d’ Olonne: L’ avant-pied rhumatoide, luxation des PTH, fracture des deux os de l’ avant-bras de l’ enfant. Ann Orthop Ouest. 2002:93-97. (Fre).
24 Ilahi OA, Cosculluela PE, Ho DM. Classification of anterosuperior glenoid labrum variants and their association with shoulder pathology. Orthopedics. 2008;31(3):226. [pmid: 19292248].
25 Jost B, Pfirrmann CW, Gerber C, et al. Clinical outcome after structural failure of rotator cuff repairs. J Bone Joint Surg Am. Mar. 2000;82(3):304-314. [pmid: 10724223].
26 Jost B, Zumstein M, Pfirrmann CW, et al. Long-term outcome after structural failure of rotator cuff repairs. J Bone Joint Surg Am. 2006;88(3):472-479. [pmid: 16510810].
27 Kadic MA, Rozing PM, Obermann WR, et al. A surgical approach in total shoulder arthroplasty. Arch Orthop Trauma Surg. 1992;111(4):192-194. [pmid: 1622706].
28 Klein SM, Steele SM, Nielsen KC, et al. The difficulties of ambulatory interscalene and intra-articular infusions for rotator cuff surgery: a preliminary report. Can J Anaesth. 2003;50(3):265-269. [pmid: 12620950].
29 Lehuec JC, Liquois F, Schaeverbecke T, et al. Résultats d’une series de lambeaux deltoidiens pour rupture massive de la coiffe des rotateurs avec 3,5 ans recul moyen [Results of a series of deltoid flaps for the treatment of massive rotator cuff tears with 3.5 years follow-up]. Rev Chir Orthop Reparatrice Appar Mot. 1996;82(1):22-28. (Fre). [pmid: 8762985].
30 Longo UG, Franceschi F, Ruzzini L, et al. Higher fasting plasma glucose levels within the normoglycaemic range and rotator cuff tears. BJSM online. 2009;43(4):284-287.
31 Lu XW, Verborgt O, Gazielly DF. Long-term outcomes after deltoid muscular flap transfer for irreparable rotator cuff tears. J Shoulder Elbow Surg. 2008;17(5):732-737. [pmid: 18644738].
32 Mansat M. Place des lambeaux musculo-tendineux dans les ruptures irreparables de la coiffe des rotateurs de l’ epaule. Enseignement de la chirurgie de la main. 1996;8:119-129. (Fre).
33 Mansat P. Societe francaise de chirurgie orthopedique et traumatologique PFo. Protheses humerales simples pour le traitement des omarthroses avec rupture de la coiffe des rotateurs. 81e reunion annuelle de la Societe francaise de chirurgie orthopedique et traumatologique. Rev Chir Orthop Reparatrice Appar Mot. S51. 2007;93(6):3-3S. 56. (Fre).
34 Oh DK, Yoon YC, Kwon JW, et al. Comparison of indirect isotropic MR arthrography and conventional MR arthrography of labral lesions and rotator cuff tears: a prospective study. Am J Roentgenol. 2009;192(2):473-479. [pmid: 19155413].
35 Postacchini F, Gumina S. Results of surgery after failed attempt at repair of irreparable rotator cuff tear. Clin Orthop Relat Res. Apr. 2002;(397):332-341.
36 Razmjou H, Holtby R, Alexander P, Moola F, et al. Size of Tear as a Prognostic Indicator for Outcome Following Rotator Cuff Full-Thickness Tear Repair. 61st Annual Meeting of the Canadian Orthopaedic Association. Toronto, ON. Jun 2–4, 2006.
37 Reinold MM, Macrina LC, Wilk KE, et al. The Effect of Electrical Stimulation of the Intraspinatus on Shoulder External Rotation Force Production Following Rotator Cuff Repair Surgery. J Orthop Sports Phys Ther. Jan. 2005;35(1):a79-a80.
38 Resch H, Povacz P, Ritter E, et al. Transfer of the pectoralis major muscle for the treatment of irreparable rupture of the subscapularis tendon. J Bone Joint Surg Am. 2000;82(3):372-382. [pmid: 10724229].
39 Simovitch RW, Zumstein MA, Lohri E, et al. Predictors of scapular notching in patients managed with the delta III reverse total shoulder replacement. J Bone Joint Surg Am. 2007;89(3):588-600. [pmid: 17332108].
40 Skutek M, Fremerey RW, Zeichen J, et al. Outcome analysis following open rotator cuff repair: early effectiveness validated using four different shoulder assessment scales. Arch Orthop Trauma Surg. 2000;120(7–8):432-436. [pmid: 10968533].
41 Thomazeau H, Colmar M. Lambeaux deltoidiens: resultats precoces d’ une serie continue de 35 cas [The deltoid flap. A series of 35 cases]. Ann Orthop Ouest. 1994:79-83. (Fre).
42 Thur C, Redaelli C. Die Deltoideus-Lappen Plastik: therapie der Wahl bei der grossen Rotatoren-Manschetten-Ruptur? [The deltoid flap-plasty: therapy of choice in large rotator cuff ruptures?]. Z Unfallchir Versicherungsmed. 1992;85(4):172-185. (Ger). [pmid: 1299297].
43 Toyoda H, Ito Y, Inui K, Koike T, et al. Evaluation of the rotator cuff tear with magnetic resonance arthrography. Clin Orthop Relat Res. 2005;439:109-115. [pmid: 16205148].
44 Vecchio PC, Adebajo AO, Hazleman BL. Suprascapular nerve block for persistent rotator cuff lesions. J Rheumatol. Mar. 1993;20(3):453-455. [pmid: 8478851].
45 Weber SC, Jain R, Parise C. Pain scores in the management of postoperative pain in shoulder surgery. Arthroscopy. Jan. 2007;23(1):65-72. [pmid: 17210429].
46 Weiss AP, Adams MA, Moore JR, et al. Unconstrained shoulder arthroplasty: a five-year average follow-up study. Clin Orthop Relat Res. Aug. 1990;(257):86-90.
47 Werner CML, Ruckstuhl T, Muller R, et al. Influence of psychomotor skills and innervation patterns on results of latissimus dorsi tendon transfer for irreparable rotator cuff tears. J Shoulder Elbow Surg. 2008;17(1 Suppl):S22-S28.

## Excluded – No Numeric Outcomes of Interest (N = 39)

The following studies were excluded because they did report numeric data for any of the a priori specified outcomes of interest.

1 Agnello L, Cataldo P, Letizia GA. Rehabilitation following injury of the rotator cuff. Acta Med Medit. 2003;19(1):43-47.
2 Bhatia M, Singh B, Nicolaou N, et al. Correlation between rotator cuff tears and repeated subacromial steroid injections: a case-controlled study. Ann R Coll Surg Engl. 2009;91(5):414-416. [pmid: 19409148].
3 Boyer T, Bailly A. Hopital Bichat Clinique rhumatologique Fp. Resultats du traitement arthroscopique des lesions de la coiffe: sport et appareil locomoteur. Rhumatologie. 1995;47(5):159-163. (Fre).
4 Brady PC, Arrigoni P, Burkhart SS. Evaluation of residual rotator cuff defects after in vivo single-versus double-row rotator cuff repairs. Arthroscopy. 2006;22(10):1070-1075. [pmid: 17027404].
5 Bron C. Treatment of myofascial trigger points in common shoulder disorders by physical therapy: a randomized controlled trial [ISRCTN75722066]. BMC Musculoskelet Disord. 2007;8:107. [pmid: 17983467].
6 Chen SK, Lin GT, Tien YC, et al. Greater tuberosity osteotomy for treatment of impinge rotator cuff tear. Kaohsiung J Med Sci. Apr. 2000;16(4):192-196. [pmid: 10933750].
7 Dainty K, Litchfield R, Forwell L, et al. Randomized clinical trial comparing the use of hydro-therapy to land based therapy alone following full-thickness rotator cuff repairs. (abstract). Clin J Sport Med. Jan. 2002;12(1):67-68.
8 Deutsch A, Altchek DW, Veltri DM, et al. Traumatic tears of the subscapularis tendon: clinical diagnosis, magnetic resonance imaging findings, and operative treatment. Am J Sports Med. Jan. 1997;25(1):13-22. [pmid: 9006686].
9 Deutsch AA Taylor MMA Prospective Comparison of Ethibond vs. Fiberwire Suture for Arthroscopic Rotator Cuff Repair2006 Annual Meeting of the American Academy of Orthopaedic Surgeons Chicago, IL Mar 22–26, 2006
10 Fukuda H, Hamada K, Nakajima T, et al. Partial-thickness tears of the rotator cuff: a clinicopathological review based on 66 surgically verified cases. Int Orthop. 1996;20(4):257-265. [pmid: 8872551].
11 Gartsman GM. Arthroscopic assessment of rotator cuff tear reparability. Arthroscopy. 1996;12(5):546-549. [pmid: 8902127].
12 Gazielly D. Epidémiologie. [Epidemiology of full-thickness tears of the rotator cuff, including subscapularis]. Rev Chir Orthop Reparatrice Appar Mot. 1999;85.
13 Gill TJ, McIrvin E, Kocher MS, et al. The relative importance of acromial morphology and age with respect to rotator cuff pathology. J Shoulder Elbow Surg. Jul. 2002;11(4):327-330. [pmid: 12195249].
14 Goutallier D, Postel JM, Bernageau J, et al. Fatty muscle degeneration in cuff ruptures: pre- and postoperative evaluation by CT scan. Clin Orthop Relat Res. Jul. 1994;(304):78-83.
15 Goutallier D, Postel JM. La degenerescence graisseuse des muscles des coiffes tendineuses rompues de l’ epaule. Rev Rhum Ed Fr. 1995;62(6):439-446. (Fre).
16 Grana WA, Teague B, King M, et al. An analysis of rotator cuff repair. Am J Sports Med. Sep. 1994;22(5):585-588. [pmid: 7810779].
17 Gumina S, Di GG, Bertino A, et al. Inflammatory infiltrate of the edges of a torn rotator cuff. Int Orthop. Oct. 2006;30(5):371-374. [pmid: 16601984].
18 Hardy P. Reparation endoscopique des ruptures des tendons de la coiffe des rotateurs : evaluation de la cicatrisation tendineuse a moyen terme. Congres de la Vingt et Unieme Journee de Bichat “Pathologie Mecanique et Sportive.”. 15 Mars 2008. Rhumatologie. 2008;60(1):23-28. (Fre).
19 Holibka R, Ditmar R, Holibkova A, et al. Isolated ruptures of the supraspinatus muscle. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. 2003;147(2):227-232. [pmid: 15037909].
20 Iannotti JP. Postoperative outcome assessment of the shoulder following rotator cuff repair. Elsevier Science Publishers B.V; Elsevier Science Publishing Co., Inc. 1995.
21 Lyons TR, Savoie FH, Field LD. Arthroscopic repair of partial-thickness tears of the rotator cuff. Arthroscopy. 2001;17(2):219-223. [pmid: 11172256].
22 Ma HL, Wu JJ, Lin CF, et al. Surgical treatment of full thickness rotator cuff tear in patients younger than 40 years. Chin Med J. Jun. 2000;63(6):452-458.
23 Maguire MG. Massive tears of the rotator cuff. Elsevier Science Publishers BV; Elsevier Science Publishing Co. Inc. 1995.
24 Murrell G, Walton J, Cummins C, et al. Long-term temporal outcomes following rotator cuff repair. (abstract). J Sci Med Sport. 2003;6(Suppl):5.
25 O’Holleran JD, Kocher MS, Horan MP, et al. Determinants of patient satisfaction with outcome after rotator cuff surgery. J Bone Joint Surg Am. Jan. 2005;87(1):121-126. [pmid: 15634822].
26 Olley LM, Carr AJ. The use of a patient-based questionnaire (the Oxford Shoulder Score) to assess outcome after rotator cuff repair. Ann R Coll Surg Engl. May. 2008;90(4):326-331. [pmid: 18492399].
27 Parent EC, Brennan G, Cleland J. Clinical outcomes and utilization of physical therapy services for categories of shoulder pathologies treated conservatively. 2008 Combined Sections Meeting. Nashville, Tennessee. February 6–9, 2008. J Orthop Sports Phys Ther. 2008;38(1):A18-A19.
28 Paulos LE, Kody MH. Arthroscopically enhance mini-approach to rotator cuff repair. Arthroscopy. 1991;7(3):331.
29 Postacchini F, Perugia D, Rampoldi M. Rotator cuff tears: results of surgical repair. Ital J Orthop Traumatol. 1992;18(2):173-188. [pmid: 1289283].
30 Putz R, Reichelt A. Strukturelle befunde am lig. coracoacromiale bei rotatorenmanschettenruptur, tendinosis calcarea und supraspinatussyndrom. Z Orthop Ihre Grenzgeb. 1990;128(1):46-50. (Ger). [pmid: 2138387].
31 Rubin A. Does continuous passive motion help?. Phys Sportsmed. Sep. 1996;24(9):160.
32 Sherman SL, Lyman S, Koulouvaris P, et al. Risk factors for readmission and revision surgery following rotator cuff repair. Clin Orthop Relat Res. Mar. 2008;466(3):608-613. [pmid: 18264848].
33 Shinoda T, Shibata Y, Izaki T, et al. A comparative study of surgical invasion in arthroscopic and open rotator cuff repair. J Shoulder Elbow Surg. 2009;18(4):596-599. [pmid: 19254852].
34 Silver-Bernstein C. Continuous passive motion after repair of the rotator cuff: a prospective outcome study. Phys Ther. 1999;79(1):99.
35 Simank HG, Dauer G, Schneider S, et al. Incidence of rotator cuff tears in shoulder dislocations and results of therapy in older patients. Arch Orthop Trauma Surg. May. 2006;126(4):235-240. [pmid: 16151824].
36 Tashjian RZ, Bradley MP, Tocci S, et al. Factors influencing patient satisfaction after rotator cuff repair. J Shoulder Elbow Surg. Nov. 2007;16(6):752-758. [pmid: 17964816].
37 Thompson C. Abstracts. J Athl Train. Apr. 1997;32(2):169.
38 Weber SC, Kauffman JI. All-arthroscopic vs. mini-open rotator cuff repair: Long-term follow-up. Arthroscopy Association of North America 23rd Annual Meeting. Orlando, FL. Apr 22–25, 2004.
39 Zilber S, Carillon Y, Lapner PC, et al. Infraspinatus delamination does not affect supraspinatus tear repair. Clin Orthop Relat Res. May. 2007;458:63-69. [pmid: 17308479].

## Excluded – Followup <12 Months (Operative) (N = 23)

The following operative studies were excluded because the postoperative followup duration was less than 12 months.

1 Balyk R, Luciak-Corea C, Otto D, et al. Do outcomes differ after rotator cuff repair for patients receiving workers’ compensation?. Clin Orthop Relat Res. Dec. 2008;466(12):3025-3033. [pmid: 18784971].
2 Benson RT, McDonnell SM, Rees JL, et al. The morphological and immunocytochemical features of impingement syndrome and partial-thickness rotator-cuff tear in relation to outcome after subacromial decompression. J Bone Joint Surg Br. 2009;91(1):119-123. [pmid: 19092016].
3 Brislin KJ, Field LD, Savoie FH III. Complications after arthroscopic rotator cuff repair. Arthroscopy. Feb. 2007;23(2):124-128. [pmid: 17276218].
4 Burkhart SS, Tehrany AM. Arthroscopic subscapularis tendon repair: technique and preliminary results. Arthroscopy. May. 2002;18(5):454-463. [pmid: 11987054].
5 Catasus-Clave ML, Guillen-Sola A, Diaz-Aristzabal U, et al. Isokinetic study of rotator cuff lesions: pre- and post-surgical results. Rehabil. 2007;41(1):25-29.
6 Cordasco FA, McGinley BJ, Charlton T. Rotator cuff repair as an outpatient procedure. J Shoulder Elbow Surg. Jan. 2000;9(1):27-30. [pmid: 10717859].
7 Ellenbecker TS, Elmore E, Bailie DS. Descriptive report of shoulder range of motion and rotational strength 6 and 12 weeks following rotator cuff repair using a mini-open deltoid splitting technique. J Orthop Sports Phys Ther. May. 2006;36(5):326-335. [pmid: 16715833].
8 Ellenbecker TS, Fischer DJ, Zeman D. Glenohumeral joint range of motion, rotational isokinetic strength, and functional self-report measures following all-arthroscopic rotator cuff repair. (abstract). J Orthop Sports Phys Ther. Jan. 2006;36(1):a68-a69.
9 Gumina S, Di GG, Perugia D, et al. Deltoid detachment consequent to open surgical repair of massive rotator cuff tears. Int Orthop. Feb. 2008;32(1):81-84. [pmid: 17410365].
10 Hartig A, Rojczyk M. Die arthroskopie subakromiale dekompression: anmerkungen zur indikation und operationstechnik [Arthroscopic sub-acromial decompression: comments on indications and surgical technique]. Unfallchirurg. Feb. 1993;96(2):109-115. (Ger). [pmid: 8451648].
11 Hofmann-Kiefer K, Eiser T, Chappell D, et al. Does patient-controlled continuous interscalene block improve early functional rehabilitation after open shoulder surgery?. Anesth Analg. 2008;106(3):991-996. [pmid: 18292451].
12 Jeevan R, Roy B, Neumann L, et al. The Nottingham augmentation device: an alternative approach to the management of massive rotator cuff tears?. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow 2006. Athens. Sep 20–23, 2006.
13 Kang L, Henn RF, Tashjian RZ, et al. Early outcome of Arthroscopic rotator cuff repair: a matched comparison with mini-open rotator cuff repair. Arthroscopy. 2007;23(6):573-582. [pmid: 17560471].
14 Kirkley A, Litchfield RB, Jackowski DM, et al. The use of the impingement test as a predictor of outcome following subacromial decompression for rotator cuff tendinosis. Arthroscopy. Jan. 2002;18(1):8-15. [pmid: 11774135].
15 Landreau P. Societe francaise de rhumatologie Fp. Place de l’ arthroscopie dans la chirurgie reconstructrice de la coiffe des rotateurs. Seizieme journee de Bichat “Appareil locomoteur” - 29 mars 2003. Seance pleniere (1ere partie). Rhumatologie. 2003;55(2):31-34. (Fre).
16 Leggin BG, Kelley MJ, Ramsey ML, et al. Short-term outcome following arthroscopic rotator cuff repair. (abstract). J Orthop Sports Phys Ther. Jan. 2005;35(1):a3-a4.
17 O’Connor DA, Chipchase LS, Tomlinson J, et al. Arthroscopic subacromial decompression: responsiveness of disease-specific and health-related quality of life outcome measures. Arthroscopy. 1999;15(8):836-840. [pmid: 10564861].
18 Ozbaydar MU, Bekmezci T, Tonbul M, et al. [The results of arthroscopic repair in partial rotator cuff tears]. Acta Orthop Traumatol Turc. 2006;40(1):49-55. (Tur). [pmid: 16648678].
19 Park JY, Yoo MJ, Kim MH. Comparison of surgical outcome between bursal and articular partial thickness rotator cuff tears. (abstract). J Orthop Sports Phys Ther. Sep. 2003;33(9):541.
20 Reinold MM, Macrina LC, Wilk KE, et al. The effect of neuromuscular electrical stimulation of the infraspinatus on shoulder external rotation force production after rotator cuff repair surgery. Am J Sports Med. 2008;36(12):2317-2321. [pmid: 18757763].
21 Sclamberg SG, Tibone JE, Itamura JM, et al. Six-month magnetic resonance imaging follow-up of large and massive rotator cuff repairs reinforced with porcine small intestinal submucosa. J Shoulder Elbow Surg. Sep. 2004;13(5):538-541. [pmid: 15383811].
22 Singh H. The efficacy of continuous cryotherapy on the postoperative shoulder: a prospective, randomized investigation. J Shoulder Elbow Surg. Nov. 2001;10(6):522-555. [pmid: 11743529].
23 Thur C, Julke M, Bircher HP. Die aufrichteosteotomie des akromions (AAO) als neues prinzip in der behandlung des Iimpingementsyndroms, insbesonders im zusammenhang mit der rekonstruktion von großen rotatorenmanschettenläsionen [Lifting osteotomy of the acromion as a new principle in treatment of impingement syndrome, especially in correlation with reconstruction of large rotator cuff lesions]. Unfallchirurg. Mar. 1998;101(3):176-183. (Ger). [pmid: 9577213].

## Excluded – Non-English (N = 79)

The following studies were excluded because they were published in a language other than English.

1 Akpinar S, Ozalay M, Hersekli MA, et al. Rotator manset yirtiklarinin artroskopic yardimli Mini: acik yontemle tamiri [Arthroscopic assisted mini-open rotator cuff repair]. Artroplasti Artroskopik Cerrahi. 2003;14(4):209-213. (Tur).
2 Augereau B, Grimberg J. Traitements, résulats fonctionnel et anatomique de la série [Full-thickness tears of the rotator cuff, including subscapularis: treatments, functional and anatomical results of the series]. Rev Chir Orthop Reparatrice Appar Mot. 1999;85.
3 Belgian Association for Arthroscopy ABA Bp. Rupture de la coiffe des rotateurs [Rotator cuff ruptures]. Acta Orthop Belg. 1995;61:3-36. (Fre).
4 Bellumore Y, Mansat P, Determe P, et al. Ruptures associées des tendons des muscles supra et infraspinatus [Full-thickness tears of the rotator cuff, including subscapularis: tendon ruptures of the supraspinatus and the infraspinatus muscles]. Rev Chir Orthop Reparatrice Appar Mot. 1999;85:113-117. (Fre).
5 Bezer M, Aydin N, Guven O. Humerus baainin yukari kaymasi rotator kilif cerrahisinde: prognostic bir arac olarak kullanilabilir mi? [Superior excursion of the humeral head: can it be used as a prognostic tool on rotator cuff tear surgery?]. Marmara Med J. 2006;19(1):1-5. (Tur).
6 Boehm TD, Ilg A, Werner A, et al. Langzeitergebnisse 5–13 Jahre) nach lokaler rekonstruktion und deltoideuslappenplastiken bei massiven rotatormanschettendefekten [Long-term results 5–13 years) after surgical local repair and deltoid muscle flap for massive rotator cuff tears]. Z Orthop Ihre Grenzgeb. Mar. 2004;142(2):228-234. (Ger). [pmid: 15106069].
7 Boileau P, Ahrens P. Le long biceps “en sablier” ou long biceps piege: une autre cause de douleur et de blocage de l’ epaule. Rev Chir Orthop Reparatrice Appar Mot. 2003;89(8):672-682. (Fre). [pmid: 14726833].
8 Boileau P, Coste JS, Deprey F, et al. Traitement arthroscopique des lésions non transfixiantes de la coiffe des rotateurs [Arthroscopic treatment of impingement and partial thickness tears of the rotator cuff of the shoulder]. Rev Chir Orthop Reparatrice Appar Mot. Dec. 2004;90(8 Suppl):S35-S48. (Fre).
9 Boldin C, Schippinger G. Vergleich der infekthaufigkeit zwischen resorbierbaren und nicht resorbierbaren nahtmaterialien bei rotatorenmanschetten-operationen. Aktuelle Traumatol. 2001;31(3):119-121. (Ger).
10 Brox JI, Bohmer AS, Ljunggren AE, et al. Behandling av kronisk senebetennelse i skulderen [Treatment of chronic shoulder tendinitis]. Tidsskr Nor Laegeforen. Feb. 20. 1994;114(5):575-577. 9. (Nor). [pmid: 8209342].
11 Caira SF, Melanotte PL. Le rotture isolate parziali del tendine del sovraspinoso [Partial tears of the supraspinatus tendon]. Minerva Ortop Traumatol. 1997;48(9):337-342. (Ita).
12 Candiotto S, Majoni A, Londei L, et al. Il trattamento chirurgico del conflitto subacromiale e della rottura della cuffia dei rotatori: esperienza personale in 134 casi [Surgical treatment of the impingement syndrome and of the rotator cuff tears: personal experience in 134 cases]. Reumatismo. Oct. 2002;54(4):308-315. (Ita). [pmid: 12563364].
13 Catalano PA, Castagna A, Auliso M, et al. La sindrome del conflitto subacromiale: principi di trattamento artroscopico [Subacromial impingement syndrome: arthroscopic treatment]. Ortop Traumatol Oggi. 1994;14(1):31-35. (Ita).
14 Charousset C, Duranthon LD, Grimberg J, et al. Êtude par arthroscanner de la cicatrisation tendineuse après réparation arthroscopique de la coiffe des rotateurs: analyse des facteurs prédictifs à propos d’une série consécutive de 167 réparations [Arthro-C-scan analysis of rotator cuff tears healing after arthroscopic repair: analysis of predictive factors in a consecutive series of 167 arthroscopic repairs]. Rev Chir Orthop Reparatrice Appar Mot. May. 2006;92(3):223-233. (Fre). [pmid: 16910604].
15 Cossu M, Spagnolo R, Bardelli D. L‘intervento riabilativo nei pazienti sottoposti ad acromioplastica secondo Rockwood [Rehabilitative treatment in patients who have undergone acromioplasty according to Rockwood]. Riabilitazione. 1998;31(1):3-12. (Ita).
16 Coudane H, Vauge L, Nicoud C, et al. Les ruptures associées des supscapularis, supraspinatus et infraspinatus [Full-thickness tears of the rotator cuff, including subscapularis: ruptures of the subscapularis, supraspinatus and infraspinatus]. Rev Chir Orthop Reparatrice Appar Mot. 1999;85:127-132. (Fre).
17 Demirhan M, Atalar AC, Kocabey Y, et al. Rotator manset yirtiklarinin artroskopik yardimli mini-acik yöntemle tamiri [Arthroscopic-assisted mini-open rotator cuff repair]. Acta Orthop Traumatol Turc. 2002;36(1):1-6. (Tur). [pmid: 12510103].
18 DeSimoni C, Ledermann T, Imhoff AB. Holmium: YAG-Laser beim “outlet impingement” der Schulter [Holmium:YAG laser treatment of outlet impingement syndrome: medium-term results]. Orthopade. 1996;25(1):84-90. (Ger). [pmid: 8622851].
19 Fabis J, Zwierzchowski H. Ocena punktowa Constanta reconstrukjci piercienia rotatorów [Constant point evaluation for reconstruction of the rotator cuff]. Chir Narzadow Ruchu Ortop Pol. 1997;62(6):491-496. (Pol). [pmid: 9501660].
20 Frank A. Societe francaise de rhumatologie PFp. Ruptures transfixiantes de la coiffe des rotateurs: decompression sous-acromiale sans reparation: Quelles coiffes faut-il reparer et comment ?. Quinzieme Journee de Bichat : sport et appareil locomoteur, 23 mars 2002. 1ere partie. Rhumatologie. 2002;54(2):16-24. (Fre).
21 Fukuda K. [Results of the operative producers of the rotator cuff tear: prospective study of the effect of postoperative local injection of sodium hyaluronate]. Yakuri to Chiryo (Japanese Pharmacology and Therapeutics). 2000;28(9):819-823. (Jpn).
22 Fukushima S, Okamura K, Usui M, et al. [Arthroscopic surgical treatment for subacromial impingement syndrome]. Hokkaido Journal of Orthopedic and Traumatic Surgery. 1995;38(1):22-25. (Jpn).
23 Gazielly DF. Resultats fonctionnels et anatomiques apres traitement chirurgical des ruptures de la coiffe des reacteurs. I: evaluation fonctionnelle et anatomique preoperatoire des ruptures de la coiffe des rotateurs [Functional and anatomic results following surgical treatment of rotator cuff tears. I: preoperatoire functional and anatomic assessment]. Rev Chir Orthop Reparatrice Appar Mot. 1995;81(1):8-16. (Fre). [pmid: 7569183].
24 Gleyze P, Augereau B, Gazielly DF. Méthodologie [Methodology in full-thickness tears of the rotator cuff, including subscapularis]. Rev Chir Orthop Reparatrice Appar Mot. 1999;85:90-92. (Fre).
25 Gleyze P, Thomazeau H. Societe Francaise d‘-Arthroscophie F. Reparation endoscopique des ruptures de la coiffe des rotateurs. Etude des facteurs predictifs du resultat anatomique et fonctionnel: a propos de 87 cas. Rev Chir Orthop Reparatrice Appar Mot. 2000;86(6):566-574. (Fre). [pmid: 11060430].
26 Gosak A. Síndrome de fricción subacromial: cirugía artroscópia. [Arthroscopic subacromial decompression: a prospective analysis of 62 patients]. Prensa Med Argent. 2001;88(10):1030-1035. (Spa).
27 Goutallier D. Quelles ruptures transfixiantes de la coiffe des rotateurs doivent etre reparees? Pourquoi, quand, comment?. Cahiers d‘enseignement de la SOFCOT. 2003;82:1-14. (Fre).
28 Gschwend N, Bloch HR, Bischof A. Langzeitergebnisse der operierten rotatormanschettenruptur [Long-term results of surgical management of rotator cuff rupture]. Orthopade. Sep. 1991;20(4):255-261. (Ger). [pmid: 1945402].
29 Hermann B, Steiner D, Van TD. Operative therapie und ergebnisse bei rotatormanschettenruptur [Surgical treatment and results of rotator cuff tears]. Z Orthop Ihre Grenzgeb. 1990;126(6):648-651. (Ger). [pmid: 2149246].
30 Hoffmann F, Schiller M, Reif G. Arthroskopische rotatormanschettenrekonstuktion [Arthroscopic rotator cuff reconstruction]. Orthopade. Oct. 2000;29(10):888-894. (Ger).
31 Holtslag HR, Jaspers PJ, Marting LN, et al. Bevredigende resultaten van operatieve reconstructie van rotator-cuff‘ - rupturen,1984–1990 [Satisfactory results of surgical reconstruction of rotator cuff ruptures, 1984–1990 ]. Ned Tijdschr Geneeskd. Jul. 16. 1994;138(29):1462-1466. (Dut). [pmid: 8052317].
32 Huguet D. Societe orthopedique de l‘-Ouest. Suture de coiffe sous arthroscopie. 38eme reunion annuelle de la Societe orthopedique de l‘ Ouest. Saint-Malo. 9–11, juin 2005. Ann Orthop Ouest. 2006:149-154. (Fre).
33 Ibragimov D. Diagnosis and treatment of traumatic damage to the musculus supraspinatus of the shoulder. Uzbekiston Tibbiet Zhurnali. 2001:127-128. (Usb).
34 Jerosch J, Schroder M, Schneider T. Die arthroskopische resektion des AC-gelenkes (ARAC): indikationen, op-technik, ergebnisse [The arthroscopic resection of the ac-joint (ARAC):indications, Surgical technique, results]. Unfallchirurg. 1998;101(9):691-696. (Ger). [pmid: 9816978].
35 Jimenez-Martin A, Angulo-Gutierrez J, Gonzalez-Herranz J, et al. La acromioplastia con reparación del manguito rotador y sus efectos en el test de Constant tras la aplicación de plasma rico en factores de crecimiento (PRGF) [Acromioplasty with rotator cuff repair and its effects in Constant test after application of plasma rich in growth factors (PRGF)]. Trauma. 2008;19(1):6-12. (Spa).
36 Johannsen HV, Andersen NH, Sojbjerg JO, et al. Artroskopisk subakromial dekompression. [Arthroscopic subacromial decompression]. Ugeskr Laeger. Jan. 6. 1997;159(2):166-170. (Dan). [pmid: 9012088].
37 Jouve F, Graveleau N. Luxation recidivante anterieure de l‘ epaule et rupture de la coiffe des rotateurs : resultats du traitement chirurgical. Rev Chir Orthop Reparatrice Appar Mot. 2008;94(7):659-669. (Fre). [pmid: 18984123].
38 Kempf JF, Bonnomet F. Orthopaedica Belgica B. Etude multicentrique de 210 ruptures de la coiffe des rotateurs traitees par acromioplastie sous arthroscopie. Acta Orthop Belg. 1995;61:23-31. (Fre). [pmid: 8623603].
39 Kempf JF, Marcillou P, Schlemmer B. Étude des différents groupes lésionnels [Full-thickness tears of the rotator cuff, including subscapularis: results of surgical treatment of isolated ruptures of the supraspinatus]. Rev Chir Orthop Reparatrice Appar Mot. 1999;85:105-109. (Fre).
40 Kenesi C, Barbato B. Place de l‘acromioplastie dans le traitement chirurgical de la pathologie de la coiffe des courts rotateurs de l‘epaule [Place of acromioplasty in the surgical treatment of the pathology of the short rotators cuff: report of 66 cases followed from one to ten years]. Rev Rhum Mal Osteoartic. 1990;57(3):193-196. (Fre). [pmid: 2339267].
41 Kenesi C. Conception biomécanique de l‘epaule et ses conséquences chirurgicales: réfexions à propos d‘une expérience personelle sur 250 épaules opérées [Biomechanics of the shoulder joint and Its surgical consequences: a personal-experience of 250 operated patients]. Bull Acad Natl Med. 1994;178(8):1493-1507. (Fre). [pmid: 7743266].
42 Kessler MA, Lichtenberg S, Habermeyer P. Die rekonstruktion von großen rotatormanschettenrupturen Eine neue technik der Sehnenrefixation mitdem Corkscrew-Fadenankersystem [Reconstruction of big rotator cuff ruptures: a new technique of tendon refixation with the corkscrew suture anchor system]. Unfallchirurg. Oct. 2003;106(10):826-833. (Ger). [pmid: 14652725].
43 Klein W, Gassen A. Die endoskopische subakromiale dekompression bei kompletter rotatorenmanschettenruptur. Indikation, technik und nachuntersuchungsergebnisse. Arthroskopie. 1993;6(3):107-111. (Ger).
44 Ladero MF, Maestro A, Martinez N, et al. Estudio clínico-laboral de la suturas artroscópicas del manguito rotador con anclajes biodegradables [Clinical-occupational study of all-arthroscopic rotator cuff suture using biodegradable anchors]. Patologia del Aparato Locomotor. 2006;4(4):254-260. (Spa).
45 Langenhorst AMWW, Diercks RL, Eikelaar HR, et al. Passagesyndroom van de schouder bij patiënten jonger dan 40 jaar, behandeld met een partiële acromionresectie [Impingement problems of the shoulder in patients under 40 treated by partial acromioplasty]. Ned Tijdschr Geneeskd. 1990;134(21):1050-1053. (Dut). [pmid: 2366897].
46 Leblebici B, Adam M, Yapgu S, et al. [Comparing the effects of open versus closed kinetic chain scapulohumeral stability exercises in rotator cuff problems]. Turkiye Fiziksel Tip ve. Rehabilitasyon Dergisi. 2007;53(4):134-137. (Tur).
47 Machner A, Pap G, Mohrenweiser L, et al. Vergleich von 2 operationstechniken isolierter supraspinatusruptur [Comparison of 2 surgical techniques in isolated supraspinatus rupture: a matched-pair study]. Unfallchirurg. Jan. 2001;104(1):19-24. (Ger). [pmid: 11381757].
48 Mariotti U, Motta PO, Vassoney PF, et al. Decompressione sub-acromiale artroscopica versus riparazione bilanciata artroscopica nel trattamento chirurgico delle lesioni massive della cuffia dei rotatori [Arthroscopic sub-acromial decompression versus balanced arthroscopic repair in the surgical treatment of rotator cuff massive tears]. Minerva Ortop Traumatol. 2005;56(3):121-126. (Ita).
49 Midorikawa K. [The arthroscopic surgery of the shoulder: a topological and clinical study]. Igaku Kenkyu. Feb. 1993;63(1):21-31. (Jpn). [pmid: 8328260].
50 Milano G, Deriu L, Ziranu F, et al. Il trattamento artroscopico della capsulite adesiva di spalla [Arthroscopic treatment of adhesive capsulitis of the shoulder]. Artroscopia. 2004;5(2):70-79. (Ita).
51 Miyazaki AN, Doneux SP, Saito RY, et al. Acromioplastia artroscópia e reparo das lesđes do manguito rotador por “miniincisão” [Arthroscopic acromioplasty and repair of rotator cuff tears using the ‘mini-open‘ approach]. Rev Bras Ortop. 1999;37(7):415-420. (Por).
52 Musil D, Sadovsky P. Masivni ruptura rotátorové manzety: srovnáni mini-open a artroskopické rekonstrukce. Cast 2: artroskopicka rekonstrukce [Massive tears of the rotator cuff: comparison of mini-open and arthroscopic techniques. Part 2: arthroscopic repair]. Acta Chir Orthop Traumatol Cech. Oct. 2007;74(5):318-325. (Cze). [pmid: 18001628].
53 Orsi R, De TV, Barisone P, et al. Personal experience in the treatment of ‘painful shoulder’. Minerva Ortop Traumatol. 1994;45(9):399-402. (Ita).
54 Orsi R, Nastro M, Brignolo M, et al. Risultati a medio termine della riparazione della cuffia dei rotatori. Verifica clinica e strumentale [Medium terms results of surgical repair of the rotator cuff]. Minerva Ortop Traumatol. 1997;48:1-2. 7. 12. (Ita).
55 Pechoucek J. Faktory ovlivnujici operacni vysledky lecby roztrzene manzety rotatoru ramena [Factors affecting the surgical results of treatment of rotator cuff tears in the shoulder]. Acta Chir Orthop Traumatol Cech. Feb. 1990;57(1):34-39. (Cze). [pmid: 2336906].
56 Postel JM. Les ruptures isolees du sous-scapulaire: manifestations osteo-articulaires et sport. Rev Rhum Ed Fr. 1998;65(7):79-84. (Fre).
57 Pouget G, Thomazeau H. Ruptures transfixiantes de la coiffe des rotateurs. Ann Orthop Ouest. 2001:171-204. (Fre).
58 Prochazka P. Vysledky artroskopické subakromiálni dekomprese u padesátiletých pacientu [Results of arthroscopic subacromial decompression in fifty-year old patients]. Acta Chir Orthop Traumatol Cech. 2001;68(1):39-44. (Cze). [pmid: 11706713].
59 Russo A, Coari GC, Raffelini F, et al. Ricostruzione artroscopica delle rotture complete di grandezza piccola e media del sopraspinato: risultati a distanza di 2–6 anni [Arthroscopic repair of small to medium full thickness supraspinatus tears: outcome at 2 to 6 year follow up]. Artroscopia. 2004;5(1):11-17. (Ita).
60 Seelig W, Kohler O, Gaechter A. Treatment of rotator cuff ruptures. Laffer U, Duerig M, Regazzoni P, editors. Basler Beitraege Zur Chirurgie, Band 3 Traumatologie und Rehabilitation. I Bewegungsapparat. (Basel Contributions to Surgery, Vol 3 Traumatology and Rehabilitation: I Locomotor Apparatus). Switzerland. 1991:82-92. (Ger).
61 Skutek M, Zeichen J, Fremerey RW, et al. Outcomeanalyse nach offener rekonstruktion von rotatorenmanschettenrupturen: eine vergleichende beurteilung neuer bewertungsverfahren [Outcome analysis after open reconstruction of rotator cuff ruptures: comparative assessment of recent evaluation procedures]. Unfallchirurg. Jun. 2001;104(6):480-487. (Ger). [pmid: 11460452].
62 Societe francaise d‘-arthroscopie. Résumés des communications. Rev Chir Orthop Reparatrice Appar Mot. S76. 2004;90(8):3-3S. 95. (Fre).
63 Sonnery-Cottet B, Edwards B. Resultats du traitement chirurgical des ruptures de coiffe des rotateurs chez le tennisman veteran. J Traumatol Sport. 2001;18(2):70-76. (Fre).
64 Steinbeck J, Halm H, Jerosch J, et al. Die ergebnisse der endoskopischen subacromialen dekompressionsoperation (ESD) bei tendinitis und partialruptur der rotatorenmanschette [Outcome of endoscopic subacromial decompression operation in tendinitis and partial rupture of the rotator cuff]. Z Orthop Ihre Grenzgeb. Jan. 1998;136(1):8-12. (Ger). [pmid: 9563179].
65 Steinbeck J, Schneider M, Potzl W, et al. Vergleichende untersuchung der ergebnisse nach der offenen naht kompletter rotatorenmanschettendefekte mit und ohne resektion der lateralen klavikula [Comparison of the results of the surgical repair of full-thickness tears of the rotator cuff with and without resection of the lateral clavicle]. Z Orthop Ihre Grenzgeb. Jul. 2002;140(4):385-389. (Ger). [pmid: 12183786].
66 Sudkamp NP. Offene oder geschlossene Akromioplastik? Arthroskopische Chirurgie im Schulter- und Kniegelenkbereich. Hefte Unfallheilkd. 1994:57-67. (Ger).
67 Tascioglu F, Dalkiran I, Oner C. Parsiyel supraspinatus tendon tupturu olan subakromiyal sikisma sendromlu hastalarda dusuk doz lazer tedavisinin etkinligi [The efficacy of low-level laser in the treatment of subacromial impingement syndrome due to partial rupture of the supraspinatus tendon]. Turkiye Fiziksel Tip ve. Rehabilitasyon Dergisi. 2003;49(6):18-22. (Tur).
68 Teissier J, Gaudin P. Resultats de la reparation chirurgicale par tendon artificiel des larges ruptures de la coiffe des rotateurs: a propos de 38 patients ayant un recul de plus de 2 ans. Rev Chir Orthop Reparatrice Appar Mot. 1992;78:175-276. (Fre).
69 Thomazeau H, Gleyze P, Societe ff-A. Arthroscopie dans les ruptures transfixiantes de la coiffe des rotateurs: resultats du Symposium de la SFA 1997. Congres sport et appareil locomoteur. Rhumatologie. 1998;50:4-5. 131. 139. (Fre).
70 Urbanek L, Karjagin V. Artoskopicka subakromialni dekomprese: vlastni zkusenosti a vysledky [Arthroscopic subacromial decompression: our experience and outcomes]. Acta Chir Orthop Traumatol Cech. 2004;71(1):45-49. (Cze). [pmid: 15069862].
71 Urbanek L, Vanecek V, Vasek P, et al. Artroskopicka paliativni resekce rotatorove manzety u nerekonstruovatelnych lezi [Arthroscopic palliative resection of the rotator cuff in patients with unreconstructible lesions]. Acta Chir Orthop Traumatol Cech. Aug. 2007;74(4):268-272. (Cze). [pmid: 17877944].
72 Valente A, Quaglia F, Ravera R. Lesioni della cuffia dei rotatori: trattamento artrotomico o artroscopico? [Lesions to the cuff of the rotator muscles: arthrotomic or arthroscopic treatment?]. Minerva Ortop Traumatol. 2006;57(2):21-26. (Ita).
73 Vitullo A, Anzini M, Sgrambiglia R, et al. Riparazione artroscopica delle lesioni della cuffia dei rotatori: risultati a breve termine [Arthroscopic rotator cuff repair: results at short follow up]. Artroscopia. 2004;5(1):18-24. (Ita).
74 von Engelhardt LV, von FM, Fahmy U, et al. MRT nach rekonstruktion der supraspinatussehne: MR-tomographische befunde [MRI after reconstruction of the supraspinatus tendon: MR-tomographic findings]. Z Orthop Ihre Grenzgeb. Sep. 2004;142(5):586-591. (Ger). [pmid: 15472769].
75 Vontobel B, Simmen BR, Munzinger U, et al. Die arthroskopische behandlung des subakromialen impingementsyndroms: moglichkeiten und grenzen [Arthroscopic treatment of subacromial impingement syndrome: possibilities and limitations]. Schweiz Rundsch Med Prax. Jan. 26. 1993;82(4):99-105. (Ger). [pmid: 8434204].
76 Walch G, Nove-Josserand L. Orthopaedica Belgica B. Reparation chirurgicale des ruptures totales de la coiffe des rotateurs: resultats et limites. Acta Orthop Belg. 1995;61:17-20. (Fre). [pmid: 8623597].
77 Wollmerstedt N, Bohm DT, Kirschner S, et al. Prufung eines einfachen Schulterfunktionstests an operativ behandelten Patienten mit Rotatorenmanschettendefekt [Evaluation of a simple test for shoulder function in patients with surgically treated rotator cuff injuries]. Z Orthop Ihre Grenzgeb. Jul. 2005;143(4):468-474. (Ger). [pmid: 16118764].
78 Yesin I, Demirhan M, Sahinkaya S. Artroskopik subakromial dekompresyon ve mini-acik rotator manset tamiri yapilmis hastalarda rehabilitasyon sonuclarimiz [Rehabilitation results of patients whom their arthroscopic subacromial decompression and mini-open repair of the rotator cuff are made]. [Abstract]. Fizyoterapi Rehabilitasyon. Dec. 2001;12(3):134-135. (Tur).
79 Zamora-Navas P, Borras Verdera A, Vargas MV, et al. Rehabilitacion en las lesiones del tendon del musculo supraespinoso. Rehabil. 2001;35(3):171-174. (Spa).

## Excluded–Multiple Publication (N = 13)

The following articles were excluded because they were multiple publications of studies already included in the review.

1 Flurin PH, Landreau P, Gregory T, et al. Reparation arthroscopique des ruptures transfixiantes de la coiffe des rotateurs: etude retrospective multicentrique de 576 cas avec controle de la cicatrisation [Arthroscopic repair of full-thickness cuff tears: a multicentric retrospective study of 576 cases with anatomical assessment]. Rev Chir Orthop Reparatrice Appar Mot. S31. 2005;91(8 Suppl):4-4S. 42. (Fre).
2 Galatz LM, Griggs S, Cameron BD, et al. Prospective longitudinal analysis of postoperative shoulder function: a ten-year follow-up study of full-thickness rotator cuff tears. J Bone Joint Surg Am. Jul. 2001;83(7):1052-1056. [pmid: 11451975].
3 Goutallier D. Surgical treatment of unrepairable associated supraspinatus and infraspinatus tears by simple suture: conclusions. Rev Chir Orthop Reparatrice Appar Mot. S168. 2004;90(5 Suppl):1-1S. 169. (Fre).
4 Goutallier D, Augereau B, Bensaida M, et al. [Surgical treatment of unrepairable associated supraspinatus and infraspinatus tears by simple suture]. Rev Chir Orthop Reparatrice Appar Mot. 2004;90(5):154-170. (Fre).
5 Hata Y, Saitoh S, Murakami N, et al. A less invasive surgery for rotator cuff tear: mini-open repair. J Shoulder Elbow Surg. Jan. 2001;10(1):11-16. [pmid: 11182730].
6 LaStayo PC, Wright TW, Jaffe R. Continuous passive motion after rotator cuff repair: a prospective outcome study [abstract]. Orthop Trans. 1997;21(1):151.
7 Leblebici B, Adam M, Bagis S, et al. Comparing the effects of open versus closed kinetic chain scapulohumeral stability exercises in patients with impingement syndrome and rotator cuff tears. Ann Rheum Dis. 2007;66(Suppl 2):574-575.
8 Liem D, Lichtenberg S, Magosch P, et al. Arthroscopic rotator cuff repair in overhead-throwing athletes. Am J Sports Med. Jul. 2008;36(7):1317-1322. [pmid: 18443274].
9 Mohtadi N, Hollinshead R, Fletcher J, et al. A randomized clinical trail comparing mini-open to open rotator cuff repair. (abstract). Clin J Sport Med. Sep. 2005;15(5):397.
10 Mohtadi NG, Hollinshead RM, Sasyniuk TM, et al. A randomized clinical trail comparing mini-open with open rotator cuff repair: two-year outcomes. (abstract). Clin J Sport Med. Mar. 2006;16(2):182.
11 Montgomery T, Savoie F, Yerger B. A comparison of arthroscopic debridement and subacromial decompression vs. open surgical repair of full-thickness tears of the rotator cuff. South Med J. 1991;84(9):2S54.
12 Rokito AS, Zuckerman JD, Gallagher MA, et al. Strength after surgical repair of the rotator cuff. J Shoulder Elbow Surg. Jan. 1996;5(1):12-17. [pmid: 8919437].
13 Tashjian RZ, Bradley MP, Tocci S, et al. A comparison of prospective and retrospective assessment of functional outcome after rotator cuff repair. J Shoulder Elbow Surg. 2008;17(6):853-859. [pmid: 18693118].

## Unobtained Studies (N = 29)

The following articles could not be obtained through the university interlibrary loan system.

14 Lazarus MD, Hoser HD. Rotator cuff repair with and without anterior acromioplasty: a prospective, randomized study [Abstract]. American Academy of Orthopaedic Surgeons 67th Annual Meeting 2000. Orlando (FL). Mar 15–19, 2000.
15 Walmsley R. Shoulder strength following surgical rotator cuff repair: a comparative analysis using isokinetic testing. JOSPT. 1992;15(0005):00215-22.
16 Neviaser TJ, Neviaser RJ, Neviaser JS. Incomplete rotator cuff tears. A technique for diagnosis and treatment. Clinical orthopaedics and related research. Sep. 1994;(306):12-16.
17 Ritacco EA, Morao LE, Zapata FO, et al. Arthroscopic subacromial decompression with “mini open” biomechanical repair. Prensa Medica Argentina. 2006;93(4):248-252.
18 Rubin A. Longer recovery for large rotator cuff tear. Physician & Sportsmedicine. 2000;28(2):29.
19 Castagna A. Arthroscopic repair of rotator cuff tears. 12th Congress of the European Society of Sports Traumatology, Knee Surgery and Arthroscopy (ESSKA 2000), Congress Innsbruck. Innsbruck. May 24–27, 2006.
20 Chudik SC, Master D, Obopilwe E, et al. Arthroscopic double-row rotator cuff repair using a knotless parachute tissue anchor. 2006. Annual Meeting of the American Academy of Orthopaedic Surgeons. Chicago, Illinois. Mar 22–26, 2006.
21 Costic RS, Lopez-Vidriero E, Gilbertson LG, et al. Double row arthroscopic rotator cuff repair: effect of suture anchor location & insertion technique. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow (SECEC-ESSSE 2006). Athens. Sep 20–23, 2006.
22 Emery R. Open repair of the rotator cuff - one and two tendon tears. 4th Congress of the European Federation of National Association of Orthopaedics and Traumatology. Brussels. Jun 3–8, 1999.
23 Fleega BA, Kovacs GE, El Shewy MO, et al. Arthroscopic repair of large and massive rotator cuff tears; 15 years follow up. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow (SECEC-ESSSE 2006). Athens. Sep 20–23, 2006.
24 Gobbi A, Zanazzo M, Constanzo D. Analysis of two different rotator cuff repair techniques with a specific rehabilitation program. 2nd European Congress of Sport Traumatology. Monte Carlo. May 1–3, 2003.
25 Handelberg F, Isenborghs S. Surgical treatment of full-thickness rotator cuff tears over the age of 60. 4th Congress of the European Federation of National Association of Orthopaedics and Traumatology. Brussels. Jun 3–8, 1999.
26 Hashiguchi H, Ito H, Banzai Y, et al. Outcomes of arthroscopic subacromial decompression alone for partial-thickness rotator cuff tear. 2006. Annual Meeting of the American Academy of Orthopaedic Surgeons. Chicago, Illinois. Mar 22–26, 2006.
27 Hibbey CS, Babos A, Nosek Z. Colliquation Tendon necrosis after rotator cuff surgery [Poster]. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow (SECEC-ESSSE 2006). Athens. Sep 20–23, 2006.
28 Madanagopal SG, Pearsall AW, Ibrahim KA. Evaluation of patients undergoing arthroscopic and mini-open rotator cuff repair: minimum two-year evaluation. 24th Annual Meeting of the Mid-America Orthopaedic Association. San Antonio, Texas. Apr 19–23, 2006.
29 Matsumoto I, Ito Y, Tomo H, et al. Advantages of novel surgical technique: arthroscopic multiple suture method, for massive rotator cuff tears. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow (SECEC-ESSSE 2006). Athens. Sep 20–23, 2006.
30 Meier SW, Manigrasso MB. Rotator cuff repair: the effect of double-row fixation on repair interface motion. 2006. Annual Meeting of the American Academy of Orthopaedic Surgeons. Chicago, Illinois. Mar 22–26, 2006.
31 Meyer M, Boru B, Rousselin B, et al. Long-term clinical and anatomical outcomes of arthroscopic repair of small and moderate-sized rotator cuff tears with magnetic resonance arthrography control. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow (SECEC-ESSSE 2006). Athens. Sep 20–23, 2006.
32 Naka Y, Ito Y, Tomo H, et al. Short-term clinical results of arthroscopic rotator cuff repair with knotless anchors. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow (SECEC-ESSSE 2006). Athens. Sep 20–23, 2006.
33 Nakamichi N, Ikegami H, Ogawa K, et al. Quantitative assessment of the rotator cuff after open bankart procedure. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow (SECEC-ESSSE 2006). Athens. Sep 20–23, 2006.
34 Nakano M, Ito Y, Tomo H, et al. Arthroscopic evaluation for delamination in full-thickness rotator cuff tears. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow (SECEC-ESSSE 2006). Athens. Sep 20–23, 2006.
35 Natsis K, Moebius U, Totlis T, et al. Complete arthroscopic repair of full thickness rotator cuff tears. 4th European Sports Medicine Congress. Lemesos. Oct 13–15, 2005.
36 Neumann L. Mini-open repair of rotator cuff tears. 12th Congress of the European Society of Sports Traumatology, Knee Surgery and Arthroscopy (ESSKA 2000), Congress Innsbruck. Innsbruck. May 24–27, 2006.
37 Nord KD, Gothelf TK. The 3D repair: anterolateral portal for retrograde suture passage in arthroscopic rotator cuff repair. 2006. Annual Meeting of the American Academy of Orthopaedic Surgeons. Chicago, Illinois. Mar 22–26, 2006.
38 O‘Holleran J, Obopilwe E, Altchek DW, et al. Tendon-bone interface force and pressure in single-row vs double-row arthroscopic rotator cuff repair. 2006. Annual Meeting of the American Academy of Orthopaedic Surgeons. Chicago, Illinois. Mar 22–26, 2006.
39 Tashjian R, Spenciner D, Leventhal E, et al. Initial fixation strength of repairs of massive rotator cuff tears. Arthroscopy. 23(7):710-716. [pmid: 17637405].
40 Weber SC, Sager R. Arthroscopic repair of partial thickness rotator cuff tears: the safety of completing the tear. AANA, Arthroscopy Association of North America 22nd Annual Meeting. Phoenix, AZ. Apr 24–28, 2003.
41 Boehm TD, Rolf O, Baumann B, et al. Age depending outcome of open rotator cuff repairs. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow (SECEC-ESSSE 2006). Athens. Sep 20–23, 2006.
42 Butcher WM, Esch JC. Arthroscopic repair of partial rotator cuff tears: a minimum 2-year follow-up. Arthroscopy Association of North America 23rd Annual Meeting. Orlando, FL. Apr 22–25, 2004.