# Methodological Quality of Included Studies

Table D-1 Methodological quality of randomized controlled trials (RCTs) and controlled clinical trials (CCTs)

Author, year | Study design, ITT | Sequence generation | Blinding | | Selective outcome reporting | Overall RoB – Pt-rated outcomes
Author, year | Study design, ITT | Sequence generation | Pt-rated outcomes | Clinical outcomes | Selective outcome reporting | Overall RoB – Pt-rated outcomes
Author, year | Study design, ITT | Allocation concealment | Incomplete outcome data | | Other sources of bias | Overall RoB – Clinical outcomes
Author, year | Study design, ITT | Allocation concealment | Pt-rated outcomes | Clinical outcomes | Other sources of bias | Overall RoB – Clinical outcomes
Bigoni M, 2009 | RCT No | Unclear | No | No | Yes | High
Bigoni M, 2009 | RCT No | Unclear | Unclear | Unclear | Unclear | High
Boehm TD, 2005 | RCT No | Yes | No | NA | Yes | High
Boehm TD, 2005 | RCT No | No | Yes | NA | Yes | NA
Brady B, 2008 | CCT Yes | No | No | No | Yes | High
Brady B, 2008 | CCT Yes | No | Unclear | Unclear | Unclear | High
Burks RT, 2009 | RCT No | Yes | No | No | Yes | High
Burks RT, 2009 | RCT No | Yes | Yes | Yes | No | High
Charousset C, 2007 | RCT No | Unclear | No | No | Yes | High
Charousset C, 2007 | RCT No | No | Yes | Yes | Unclear | High
De Carli A, 2006 | RCT No | Unclear | No | NA | No | High
De Carli A, 2006 | RCT No | Unclear | Unclear | NA | Unclear | NA
Franceschi F, 2008 | RCT Yes | Yes | No | No | Yes | High
Franceschi F, 2008 | RCT Yes | Yes | No | No | Unclear | High
Franceschi F, 2007 | RCT No | Yes | No | No | Yes | High
Franceschi F, 2007 | RCT No | Unclear | Yes | Yes | Yes | High
Franceschi F, 2007 | RCT Yes | Yes | No | No | Yes | High
Franceschi F, 2007 | RCT Yes | Yes | No | No | Yes | High
Gartsman GM, 2004 | RCT No | Yes | No | NA | Yes | High
Gartsman GM, 2004 | RCT No | Unclear | Yes | NA | Unclear | NA
Grasso A, 2009 | RCT No | Yes | No | No | Yes | High
Grasso A, 2009 | RCT No | Yes | Yes | Yes | Yes | High
Hayes K, 2004 | RCT No | Yes | No | No | Yes | High
Hayes K, 2004 | RCT No | No | No | No | Yes | High
Iannotti JP, 2006 | RCT No | Yes | No | NA | Yes | High
Iannotti JP, 2006 | RCT No | Unclear | Yes | NA | No | NA
Kim SH, 2003 | CCT No | No | No | No | Yes | High
Kim SH, 2003 | CCT No | No | Yes | Yes | Unclear | High
Klintberg IH, 2009 | RCT No | Yes | No | No | Yes | High
Klintberg IH, 2009 | RCT No | Yes | No | No | Yes | High
Ko S, 2009 | CCT No | No | No | NA | Yes | High
Ko S, 2009 | CCT No | No | Yes | NA | Yes | NA
LaStayo PC, 1998 | RCT No | Yes | No | No | Yes | High
LaStayo PC, 1998 | RCT No | Unclear | Unclear | Unclear | Yes | High
Michael JWP, 2005 | RCT Yes | Yes | No | No | Yes | High
Michael JWP, 2005 | RCT Yes | Unclear | Yes | Yes | No | High
Milano G, 2007 | RCT No | Yes | No | NA | Yes | High
Milano G, 2007 | RCT No | Yes | No | NA | Yes | NA
Mohtadi NG, 2008 | RCT Yes | Yes | No | No | No | High
Mohtadi NG, 2008 | RCT Yes | Yes | Yes | Yes | No | High
Montgomery TJ, 1994 | CCT No | No | No | No | Yes | High
Montgomery TJ, 1994 | CCT No | No | No | No | Unclear | High
Moosmayer S, 2010 | RCT yes | Yes | No | NA | Yes | High
Moosmayer S, 2010 | RCT yes | Yes | Yes | NA | Unclear | NA
Ogilvie-Harris DJ, 1993 | CCT No | No | No | NA | Yes | High
Ogilvie-Harris DJ, 1993 | CCT No | No | Unclear | NA | Yes | High
Raab MG, 1996 | RCT No | Unclear | No | NA | Yes | High
Raab MG, 1996 | RCT No | Unclear | No | NA | No | NA
Roddey TS, 2002 | RCT No | Yes | No | NA | Yes | High
Roddey TS, 2002 | RCT No | Unclear | No | NA | Yes | NA
Shibata Y, 2001 | RCT No | Unclear | No | No | Yes | High
Shibata Y, 2001 | RCT No | Unclear | Yes | Yes | Unclear | High
Torrens C, 2003 | CCT No | No | No | NA | Yes | High
Torrens C, 2003 | CCT No | No | Yes | NA | Unclear | NA

CCT = controlled clinical trial; ITT = intention-to-treat analysis; pt = patient; NA = not applicable; Pt = patient; RCT = randomized controlled trial; RoB = risk of bias

Table D-2 Methodological quality of cohort studies

Author, year | Study design | Representativeness of cohort | Ascertainment of exposure | Comparability of cohorts | Adequate duration of followup | Total Stars
Author, year | Study design | Selection of non-exposed cohort | Assessment of outcome | Comparability of cohorts | Adequate followup of cohort | Total Stars
Baker CL, 1995 | Retrospective | B (1*) | A (1*) | C (0*) | A (1*) | 5 *
Baker CL, 1995 | Retrospective | A (1*) | C (0*) | C (0*) | A (1*) | 5 *
Bennett WF, 2003 | Prospective | C (0*) | A (1*) | C (0*) | A (1*) | 4 *
Bennett WF, 2003 | Prospective | A (1*) | E (0*) | C (0*) | A (1*) | 4 *
Bishop J, 2006 | Prospective | A (1*) | A (1*) | A (1*) | A (1*) | 5 *
Bishop J, 2006 | Prospective | A (1*) | C (0*) | A (1*) | C (0*) | 5 *
Boileau P, 2007 | Retrospective | C (0*) | A (1*) | A, B (2*) | A (1*) | 6 *
Boileau P, 2007 | Retrospective | A (1*) | D (0*) | A, B (2*) | B (1*) | 6 *
Buess E, 2005 | Prospective | A (1*) | A (1*) | A (1*) | A (1*) | 6 *
Buess E, 2005 | Prospective | A (1*) | C (0*) | A (1*) | A (1*) | 6 *
Colegate-Stone T, 2009 | Prospective | B (1*) | A (1*) | C (0*) | A (1*) | 4 *
Colegate-Stone T, 2009 | Prospective | A (1*) | C (0*) | C (0*) | D (0*) | 4 *
Costouros JG, 2006 | Retrospective | B (1*) | A (1*) | A (1*) | A (1*) | 5 *
Costouros JG, 2006 | Retrospective | A (1*) | C (0*) | A (1*) | D (0*) | 5 *
Cummins CA, 2003 | Prospective | A (1*) | A (1*) | C (0*) | A (1*) | 5 *
Cummins CA, 2003 | Prospective | A (1*) | C (0*) | C (0*) | A (1*) | 5 *
Delbrouck C, 2003 | Prospective | D (0*) | A (1*) | C (0*) | B (0*) | 2 *
Delbrouck C, 2003 | Prospective | A (1*) | E (0*) | C (0*) | C (0*) | 2 *
Favard L, 2009 | Retrospective | C (0*) | A (1*) | C (0*) | A (1*) | 2 *
Favard L, 2009 | Retrospective | B (1*) | C (0*) | C (0*) | D (0*) | 2 *
Hata Y, 2004 | Retrospective | A (1*) | A (1*) | C (0*) | A (1*) | 4 *
Hata Y, 2004 | Retrospective | A (1*) | E (0*) | C (0*) | D (0*) | 4 *
Ide J, 2005 | Prospective | A (1*) | A (1*) | A (1*) | A (1*) | 7 *
Ide J, 2005 | Prospective | A (1*) | A (1*) | A (1*) | B (1*) | 7 *
Ito J, 2003 | Retrospective | B (1*) | A (1*) | C (0*) | A (1*) | 4 *
Ito J, 2003 | Retrospective | A (1*) | C (0*) | C (0*) | C (0*) | 4 *
Klinger HM, 2005 | Retrospective | C (0*) | A (1*) | C (0*) | A (1*) | 4 *
Klinger HM, 2005 | Retrospective | A (1*) | C (0*) | C (0*) | A (1*) | 4 *
Ko SH, 2008 | Prospective | B (1*) | A (1*) | C (0*) | A (1*) | 5 *
Ko SH, 2008 | Prospective | A (1*) | C (0*) | C (0*) | A (1*) | 5 *
Kose KC, 2008 | Retrospective | A (1*) | A (1*) | A (1*) | A (1*) | 5 *
Kose KC, 2008 | Retrospective | A (1*) | E (0*) | A (1*) | C (0*) | 5 *
Leroux JL, 1993 | Retrospective | B (0*) | A (1*) | C (0*) | B (0*) | 3 *
Leroux JL, 1993 | Retrospective | A (1*) | D (0*) | C (0*) | A (1*) | 3 *
Liem D, 2007 | Retrospective | A (1*) | A (1*) | A, B (2*) | A (1*) | 7 *
Liem D, 2007 | Retrospective | A (1*) | C (0*) | A, B (2*) | A (1*) | 7 *
Lunn JV, 2008 | Prospective | C (0*) | A (1*) | B (1*) | A (1*) | 5 *
Lunn JV, 2008 | Prospective | A (1*) | D (0*) | B (1*) | A (1*) | 5 *
Marc T, 2009 | Retrospective | A (1*) | A (1*) | A (1*) | A (1*) | 6 *
Marc T, 2009 | Retrospective | A (1*) | D (0*) | A (1*) | A (1*) | 6 *
Matis N, 2006 | Prospective | A (1*) | A (1*) | C (0*) | A (1*) | 4 *
Matis N, 2006 | Prospective | A (1*) | D (0*) | C (0*) | C (0*) | 4 *
McIntyre LF, 2006 | Retrospective | A (1*) | A (1*) | C (0*) | A (1*) | 4 *
McIntyre LF, 2006 | Retrospective | A (1*) | E (0*) | C (0*) | C (0*) | 4 *
Millar NL, 2009 | Retrospective | B (1*) | A (1*) | A, B (2*) | A (1*) | 7 *
Millar NL, 2009 | Retrospective | A (1*) | A (1*) | A, B (2*) | C (0*) | 7 *
Milroy DR, 2008 | Retrospective | D (0*) | A (1*) | C (0*) | B (0*) | 3 *
Milroy DR, 2008 | Retrospective | A (1*) | D (0*) | C (0*) | A (1*) | 3 *
Moser M, 2007 | Retrospective | C (0*) | A (1*) | C (0*) | A (1*) | 3 *
Moser M, 2007 | Retrospective | A (1*) | E (0*) | C (0*) | D (0*) | 3 *
Motycka T, 2004 | Retrospective | A (1*) | A (1*) | C (0*) | A (1*) | 4 *
Motycka T, 2004 | Retrospective | B (0*) | D (0*) | C (0*) | A (1*) | 4 *
Mullett H, 2006 | Prospective | B (1*) | A (1*) | C (0*) | A (1*) | 6 *
Mullett H, 2006 | Prospective | A (1*) | C (0*) | C (0*) | D (0*) | 6 *
Park JY, 2008 | Prospective | B (1*) | A (1*) | A (1*) | A (1*) | 7 *
Park JY, 2008 | Prospective | A (1*) | A (1*) | A (1*) | A (1*) | 7 *
Pearsall AW, 2007 | Prospective | A (1*) | A (1*) | A, B (2*) | A (1*) | 8 *
Pearsall AW, 2007 | Prospective | A (1*) | A (1*) | A, B (2*) | B (1*) | 8 *
Sauerbrey AM, 2005 | Retrospective | A (1*) | A (1*) | A (1*) | A (1*) | 6 *
Sauerbrey AM, 2005 | Retrospective | A (1*) | C (0*) | A (1*) | B (1*) | 6 *
Severud EL, 2003 | Retrospective | B (1*) | A (1*) | C (0*) | A (1*) | 4 *
Severud EL, 2003 | Retrospective | A (1*) | D (0*) | C (0*) | C (0*) | 4 *
Sugaya H, 2005 | Retrospective | A (1*) | A (1*) | A (1*) | A (1*) | 6 *
Sugaya H, 2005 | Retrospective | A (1*) | C (0*) | A (1*) | B (1*) | 6 *
Vad VB, 2002 | Retrospective | C (0*) | A (1*) | A (1*) | A (1*) | 5 *
Vad VB, 2002 | Retrospective | A (1*) | C (0*) | A (1*) | A (1*) | 5 *
Verma NN, 2006 | Retrospective | A (1*) | A (1*) | A, B (2*) | A (1*) | 6 *
Verma NN, 2006 | Retrospective | A (1*) | C (0*) | A, B (2*) | C (0*) | 6 *
Walton JR, 2007 | Retrospective | C (0*) | A (1*) | A, B (2*) | A (1*) | 6 *
Walton JR, 2007 | Retrospective | A (1*) | C (0*) | A, B (2*) | A (1*) | 6 *
Warner JJ, 2005 | Retrospective | B (1*) | A (1*) | C (0*) | A (1*) | 5 *
Warner JJ, 2005 | Retrospective | A (1*) | C (0*) | C (0*) | A (1*) | 5 *
Wilson F, 2002 | Retrospective | B (1*) | A (1*) | C (0*) | A (1*) | 5 *
Wilson F, 2002 | Retrospective | A (1*) | D (0*) | C (0*) | A (1*) | 5 *
Yamada N, 2000 | Retrospective | C (0*) | A (1*) | C (0*) | A (1*) | 3 *
Yamada N, 2000 | Retrospective | B (0*) | C (0*) | C (0*) | A (1*) | 3 *
Youm T, 2005 | Retrospective | A (1*) | A (1*) | A (1*) | A (1*) | 6 *
Youm T, 2005 | Retrospective | A (1*) | C (0*) | A (1*) | B (1*) | 6 *

Table D-3 Methodological quality of before-and-after (BA) studies and cohorts treated as BA studies^*^

Author, year | Study design | Patients enrolled consecutively | Incomplete outcome data adequately addressed | Standardized approach used to assess outcomes
Audenaert E, 2006 | BA | Yes | Yes | Yes
Baysal D, 2005 | BA | Unclear | No | Yes
Bennett WF, 2003 | BA | Yes | Yes | Unclear
Bennett WF, 2003 | Cohort treated as BA | Yes | Yes | Unclear
Boileau P, 2005 | BA | Yes | Yes | Yes
Boissonnault WG, 2007 | BA | Unclear | No | No
Boszotta H, 2004 | BA | No | Yes | Unclear
Caniggia M, 1995 | BA | No | Yes | Unclear
Charousset C, 2008 | BA | Yes | Yes | No
Checchia SL, 2005 | BA | Unclear | Yes | Unclear
Cofield RH, 2001 | BA | Yes | Yes | Unclear
Cole BJ, 2007 | BA | Yes | Yes | Yes
Cools A, 2006 | Cohort treated as BA | Unclear | Yes | Yes
Davidson PA, 2000 | BA | Yes | Unclear | Unclear
DeFranco MJ, 2007 | BA | Yes | Yes | No
Deutsch A, 2008 | Cohort treated as BA | Yes | Yes | Yes
Deutsch A, 2007 | BA | Yes | Yes | Yes
Ellman H, 1993 | BA | No | Yes | No
Fenlin JM, 2002 | BA | Unclear | Yes | Yes
Fuchs B, 2006 | BA | Yes | Yes | Unclear
Gartsman GM, 1998 | BA | Yes | Yes | No
Gartsman GM, 1997 | BA | Yes | Yes | No
Gazielly DF, 1994 | BA | Yes | Yes | Yes
Ghroubi S, 2008 | BA | Unclear | Unclear | Unclear
Gladstone JN, 2007 | BA | Unclear | Yes | Yes
Hawkins RH, 1995 | BA | Yes | No | Yes
Heers G, 2005 | BA | Unclear | Yes | Unclear
Henn RF III, 2008 | Cohort treated as BA | Unclear | Unclear | Unclear
Hsu SL, 2007 | BA | Yes | Yes | Unclear
Iannotti JP, 1996 | BA | Yes | Yes | Yes
Ide J, 2007 | BA | Yes | Yes | Yes
Ide J, 2005 | BA | Yes | Yes | Yes
Kane TP, 2008 | BA | Yes | Unclear | Unclear
Kirschenbaum D, 1993 | BA | Unclear | Yes | Yes
Klepps S, 2004 | BA | Yes | No | Yes
Klinger HM, 2005 | BA | Yes | Yes | Yes
Koubaa S, 2006 | BA | Unclear | Unclear | Unclear
Kreuz PC, 2005 | BA | Unclear | Yes | Unclear
Lafosse L, 2007 | BA | Yes | Yes | Unclear
Lafosse L, 2007 | BA | Yes | Yes | Yes
Levy O, 2008 | BA | Yes | Unclear | Unclear
Levy O, 2008 | BA | Unclear | Yes | Unclear
Lichtenberg S, 2006 | BA | Yes | Unclear | Unclear
Liem D, 2008 | BA | Yes | Yes | Unclear
Lim JT, 2005 | Cohort treated as BA | Yes | Yes | Yes
Maier D, 2007 | BA | Unclear | Yes | Yes
Mallon WJ, 2004 | Cohort treated as BA | Yes | Yes | Yes
McBirnie JM, 2005 | BA | Unclear | Yes | Unclear
McCallister WV, 2005 | BA | Yes | No | No
Misamore GW, 1995 | Cohort treated as BA | Yes | Yes | Unclear
Nam SC, 2008 | Cohort treated as BA | Unclear | Yes | Yes
Nho SJ, 2009 | BA | Yes | No | Unclear
Oh JH, 2008 | Cohort treated as BA | Yes | Yes | Yes
Pai VS, 2001 | BA | Yes | Yes | Yes
Park JY, 2004 | Cohort treated as BA | Yes | Yes | Unclear
Pillay R, 1994 | Cohort treated as BA | Unclear | Unclear | No
Porcellini G, 2006 | Cohort treated as BA | Yes | Yes | Yes
Prasad N, 2005 | BA | Yes | Yes | Yes
Randelli PS, 2008 | BA | Unclear | Yes | Unclear
Rokito AS, 1999 | BA | Yes | Yes | Yes
Rokito AS, 1996 | BA | Yes | Yes | Unclear
Scheibel M, 2007 | BA | Unclear | Yes | Unclear
Scheibel M, 2004 | BA | Unclear | Yes | Unclear
Scheuermann R, 1991 | BA | Unclear | Yes | Unclear
Sugaya H, 2007 | BA | Yes | Unclear | Unclear
Tashjian RZ, 2008 | BA | Unclear | Unclear | No
Tashjian RZ, 2006 | BA | Yes | No | No
Tauro JC, 2006 | Cohort treated as BA | Yes | Yes | Unclear
Tauro JC, 2004 | BA | Yes | Yes | No
Trenerry K, 2005 | Case control treated as BA | Yes | Yes | Unclear
Vaz S, 2000 | BA | Unclear | Yes | Yes
Vitale MA, 2007 | BA | Unclear | Yes | No
Waibl B, 2005 | BA | Yes | Yes | Unclear
Zumstein MA, 2008 | BA | Yes | Yes | Yes

* Cohort for which groups were combined in our analysis and, therefore, considered functionally equivalent to BA studies