# Review Forms

C1. Eligibility Criteria

C2. Methodological Quality Assessment

Randomized Controlled Trials and Controlled Clinical Trials

Cohort Studies

Case-Control Studies

Before-and-After Studies

C3. Data Extraction