# Literature Search Strings

Table B-1 MEDLINE^®–^ Ovid Version

OvidSP_UI02.01.02.102 1950 to January Week 4 2009 | Searched: 27Jan09 and 15Sep09 Results: 2291
1. exp rotator cuff/in 2. ((rotator cuff^*^ or rotator interval^*^ or supraspin?tus or infraspin?tus or “teres minor” or subscapularis or anterosuperior or posterosuperior) adj5 (tear or tears or tore or torn or lesion^*^ or rupture^*^ or avuls^*^ or injur^*^ or repair^*^ or debride^*^)).mp. 3. exp tendon injuries/ 4. exp Muscles/in 5. ((tendon or tendons or muscle^*^ or muscular) adj5 (tear or tears or tore or torn or lesion^*^ or rupture^*^ or avuls^*^ or injur^*^ or repair^*^ or debride^*^)).mp. 6. ((full or partial) adj4 (thick$ or tear or tears)).ti,ab. 7. or/3–6 8. exp Shoulder/ or exp Shoulder Joint/ 9. (shoulder or glenohumeral).mp. 10. (rotator cuff^*^ or rotator interval^*^ or supraspin?tus or infraspin?tus or “teres minor” or subscapularis or anterosuperior or posterosuperior).mp. 11. or/8–10 12. 7 and 11 13. or/1–2,12 14. randomized controlled trial.pt. 15. controlled clinical trial.pt. 16. exp randomized controlled trials as topic/ 17. exp Random Allocation/ 18. exp Double-Blind Method/ 19. exp Single-Blind Method/ 20. clinical trial.pt. 21. exp clinical trials as topic/ 22. (clin$ adj25 (trial$ or study or studies or design)).ti,ab. 23. ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab. 24. exp placebos/ 25. placebo$.ti,ab. 26. random$.ti,ab. 27. exp research design/ 28. comparative study/ 29. exp evaluation studies/ | 30. exp follow-up studies/ 31. ((follow$ or observational or compar$) adj3 (trial$ or study or studies or design)).ti,ab. 32. exp prospective studies/ 33. exp epidemiologic studies/ 34. exp causality/ 35. epidemiological factors/ 36. (effect$ or outcome$ or allocat$ or control$ or assign$ or compar$ or experiment$ or analys$ or analyz$).mp. 37. ((control$ or prospectiv$ or volunteer$ or participant$) adj5 (trial$ or study or studies or design)).mp. 38. (group or groups).ti,ab. 39. cohort$.ti,ab. 40. case-control$.ti,ab. 41. cross sectional.ti,ab. 42. (case adj (comparison or referent$ or series)).ti,ab. 43. longitudinal.ti,ab. 44. (causation or causal$).ti,ab. 45. (analytic adj (study or studies)).mp. 46. “single subject”.ti,ab. 47. SSRD.ti,ab. 48. “n-of-1”.ti,ab. 49. baseline.ti,ab. 50. “before after”.ti,ab.^*^ 51. or/14–50 52. animals/ not humans/ 53. 51 not 52 54. 13 and 53 55. limit 54 to (“all adult (19 plus years)” or “adult (19 to 44 years)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”)

* Line removed for Sept 2009 search

Table B-2 EMBASE—Ovid Version

OvidSP_UI02.01.02.102 1988 to 2009 Week 3 | Searched: 27Jan09 and 15Sep09 Results: 2247
1. exp rotator cuff rupture/ 2. ((rotator cuff^*^ or rotator interval^*^ or supraspin?tus or infraspin?tus or “teres minor” or subscapularis or anterosuperior or posterosuperior) adj5 (tear or tears or tore or torn or lesion^*^ or rupture^*^ or avuls^*^ or injur^*^ or repair^*^ or debride^*^)).mp. 3. exp tendon injury/ or exp tendon rupture/ or exp ligament rupture/ 4. exp Muscle injury/ 5. ((tendon or tendons or muscle^*^ or muscular) adj5 (tear or tears or tore or torn or lesion^*^ or rupture^*^ or avuls^*^ or injur^*^ or repair^*^ or debride^*^)).mp. 6. ((full or partial) adj4 (thick$ or tear or tears)).ti,ab. 7. or/3–6 8. exp Shoulder/ or exp Rotator Cuff/ or “teres minor muscle”/ 9. (shoulder or glenohumeral).mp. 10. (rotator cuff^*^ or rotator interval^*^ or supraspin?tus or infraspin?tus or “teres minor” or subscapularis or anterosuperior or posterosuperior).mp. 11. or/8–10 12. 7 and 11 13. or/1–2,12 14. exp randomized controlled trial/ 15. exp Randomization/ 16. exp controlled clinical trial/ 17. (clin$ adj25 (trial$ or study or studies or design)).ti,ab. 18. ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab. 19. exp placebo/ 20. placebo$.ti,ab. 21. random$.ti,ab. 22. (ae or co or ct or do or th).fs. | 23. exp Methodology/ 24. exp Types of study/ 25. exp “evaluation and Follow-up”/ 26. ((follow$ or observational or compar$) adj3 (trial$ or study or studies or design)).ti,ab. 27. (effect$ or outcome$ or allocat$ or control$ or assign$ or compar$ or experiment$ or analys$ or analyz$).mp. 28. ((control$ or prospectiv$ or volunteer$ or participant$) adj5 (trial$ or study or studies or design)).mp. 29. (group or groups).ti,ab. 30. cohort$.ti,ab. 31. case-control$.ti,ab. 32. cross sectional.ti,ab. 33. (case adj (comparison or referent$ or series)).ti,ab. 34. longitudinal.ti,ab. 35. (causation or causal$).ti,ab. 36. (analytic adj (study or studies)).mp. 37. (epidemiologic$ adj (study or studies)).ti,ab. 38. “single subject”.ti,ab. 39. SSRD.ti,ab. 40. “n-of-1”.ti,ab. 41. baseline.ti,ab. 42. “before after”.ti,ab.^*^ 43. or/14–42 44. Nonhuman/ not human/ 45. 43 not 44 46. 13 and 45 47. limit 46 to (adult <18 to 64 years> or aged <65+ years>) 48. limit 47 to yr=“1990 – 2009”

* Line removed for Sept 2009 search

Table B-3 EBM Reviews—Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effectiveness, Health Technology Assessment Database—Ovid Version

OvidSP_UI02.01.02.102 4th Quarter 2008 | Searched: 28Jan00 and 15Sep09** Results: 220
Central**: 165 CDSR: 35 | DARE: 11 HTA: 9
1. exp rotator cuff/in 2. ((rotator cuff* or rotator interval* or supraspin?tus or infraspin?tus or “teres minor” or subscapularis or anterosuperior or posterosuperior) adj5 (tear or tears or tore or torn or lesion* or rupture* or avuls* or injur* or repair* or debride*)).mp. 3. exp tendon injuries/ or exp tendon injury/ or exp tendon rupture/ or exp ligament rupture/ 4. exp Muscles/in or exp Muscle Injury/ 5. ((tendon or tendons or muscle* or muscular) adj5 (tear or tears or tore or torn or lesion* or rupture* or avuls* or injur* or repair* or debride*)).mp. | 6. ((full or partial) adj4 (thick$ or tear or tears)).ti,ab. 7. or/3–6 8. exp Shoulder/ or exp Shoulder Joint/ or exp Rotator Cuff/ or “teres minor muscle”/ 9. (shoulder or glenohumeral).mp. 10. (rotator cuff* or rotator interval* or supraspin?tus or infraspin?tus or “teres minor” or subscapularis or anterosuperior or posterosuperior).mp. 11. or/8–10 12. 7 and 11 13. or/1–2,12 14. limit 13 to yr=“1990 – 2008”

Table B-4 AMED (Allied and Complementary Medicine) and Pascal—Ovid Version

OvidSP_UI02.01.02.102 AMED 1910 to January 2009 Searched: 28Jan09 Results: 131 | Pascal 1987 to Jan 2009 Searched: 28Jan09 Results: 751
1. exp rotator cuff/in 2. ((rotator cuff* or rotator interval* or supraspin?tus or infraspin?tus or “teres minor” or subscapularis or anterosuperior or posterosuperior) adj5 (tear or tears or tore or torn or lesion* or rupture* or avuls* or injur* or repair* or debride*)).mp. 3. exp tendon injuries/ 4. exp Muscles/in 5. ((tendon or tendons or muscle* or muscular) adj5 (tear or tears or tore or torn or lesion* or rupture* or avuls* or injur* or repair* or debride*)).mp. 6. ((full or partial) adj4 (thick$ or tear or tears)).ti,ab. 7. or/3–6 8. exp Shoulder/ or exp Shoulder Joint/ 9. (shoulder or glenohumeral).mp. 10. (rotator cuff* or rotator interval* or supraspin?tus or infraspin?tus or “teres minor” or subscapularis or anterosuperior or posterosuperior).mp. 11. or/8–10 12. 7 and 11 13. or/1–2,12 | 14. limit 13 to yr=“1990 – 2009” 15. child*.ti. 16. 14 not 15 17. remove duplicates from 16 18. from 17 keep 1–1782 19. limit 18 to (atlas or bibliography or case report clinical case or comments or correspondence letters or deposited material or editorial or excerpt or expert view or interview talk or legislation or letter to editor or “map” or numerical data or offprint or preliminary communication or short communication or standard or thoughts about synopsis or trade literature) 20. 18 not 19 21. from 17 keep 1783–2049 22. limit 21 to (annotated bibliography or bibliography or brief communication or clinical note or commentary or editorial or equipment note or “equipment review” or interview or lecture or letter or monograph or news or notes or study guide or technical note) 23. 21 not 22 24. 20 or 23

Table B-5 EBSCO Databases

Searched: 04Feb09 and 15Sep09** | | Results: 895
Database | | Years Searched | Number of Results
CINAHL® (Cumulative Index to Nursing & Allied Health Literature)** | | 1937 to 2008 | 93
SPORTDiscus with Full Text | | 1800 to 2008 | 428
Academic Search Elite | | 1985 to 2008 | 327
Health Source: Nursing and Academic Edition | | | 47
S6 | S4 not S5 Limiters - Published Date from: 199001–200912; Publication Type: Periodical, Book, Primary Source Document; Document Type: Abstract, Article, Proceeding; Exclude MEDLINE records; Publication Type: Abstract, Book Chapter, Clinical Trial, Doctoral Dissertation, Journal Article, Masters Thesis, Nursing Interventions, Proceedings, Research, Review, Systematic Review; Age Groups: Adult, 19–44 years, Middle Age, 45–64 years, Aged, 65+ years, Aged, 80 and over, All Adult; Clinical Queries: Therapy - High Sensitivity; Publication Type: Journal Article, Monograph or government document, Serial publication, Thesis or dissertation
S5 | TI ( child* or pediatr* or paediatr* ) or SU ( child* or pediatr* or paediatr* )
S4 | ( (S1 or S2) ) and S3
S3 | tear or tears or tore or torn or lesion* or rupture* or avuls* or repair* or debride* or full-thickness or partial-thickness or thickness
S2 | MH “Glenohumeral Joint/IN”
S1 | “rotator cuff*” or DE “SHOULDER joint -- Rotator cuff” or supraspinatus or infraspinatus or “teres minor” or subscapularis or MH “Rotator Cuff+” or anterosuperior or posterosuperior

Table B-6 Science Citation Index Expanded (via Web of Science^®^)—Institute for Scientific Information—Thomson Corporation

Version 7.8 1900 to 2009 Limit: 1990–2009 | | Searched: 03Feb09 Results: 3072
#24 | #23 OR #21 OR #19 OR #17 OR #15
#23 | #13 AND #22
#22 | TI=(evaluat* OR compar* OR versus OR study)
#21 | #13 AND #20
#20 | TS=(longitudinal OR cohort* OR baseline OR follow-up OR before-after OR case series OR observational OR participants OR patients)
#19 | #13 AND #18
#18 | TS=((control* or prospectiv* or volunteer* or participant*) SAME (trial* or study or studies or design))
#17 | #13 AND #16
#16 | TS=(effect$ or outcome$ or allocat$ or control$ or assign$ or compar$ or experiment$ or analys$ or analyz$)
#15 | #13 AND #14
#14 | TS= clinical trial* OR TS=research design OR TS=comparative stud* OR TS=evaluation stud* OR TS=controlled trial* OR TS=follow-up stud* OR TS=prospective stud* OR TS=random* OR TS=placebo* OR TS=(single blind*) OR TS=(double blind*)
#13 | #11 NOT #12 AND Document Type=(Article OR Meeting Abstract OR Meeting-Abstract OR Proceedings Paper OR Review)
#12 | SO=(child OR children OR paediatr* OR pediatr* OR peadiatr* OR adoles* OR teen OR teens OR teenage* OR infan* OR baby OR babies OR neonat*)
#11 | #9 NOT #10
#10 | TI=(child OR children OR paediatr* OR pediatr* OR peadiatr* OR adoles* OR teen OR teens OR teenage* OR infan* OR baby OR babies)
#9 | #8 NOT #1
#8 | #7 OR #4
#7 | #6 AND #5
#6 | TS=( shoulder or glenohumer*)
#5 | TS=((tendon or tendons or muscle* or muscular) SAME (tear or tears or tore or torn or lesion* or rupture* or avuls* or injur* or repair* or debride*))
#4 | #2 AND #3
#3 | TS=( tear OR tears OR tore OR torn or lesion* OR rupture* OR avuls* OR injur* OR repair* OR debride* OR thickness OR full-thickness OR partial-thickness)
#2 | TS=(supraspinatus OR infraspinatus OR teres minor OR subscapularis OR rotator cuff* OR anterosuperior OR posterosuperior)
#1 | TS=(veterinar* OR zoolog* OR rat OR rats OR rodent* OR mouse OR mice OR insect* OR entomolog* OR mantis* or pigeon* OR sheep OR pig OR pigs OR cow* OR bovine OR animal* OR primat* OR chimp* OR horse OR horses OR cat OR cats OR dog OR dogs OR canine OR feline)

Table B-7 Scopus^®^ Elsevier B.V.

1966 to 2009 Limit: 1990–2009 | Searched: 05Feb09 Results: 804
(TITLE-ABS-KEY(rotator cuff* OR rotator interval* OR supraspin?tus OR infraspin?tus OR “teres minor” OR subscapularis OR anterosuperior OR posterosuperior) AND TITLE-ABS-KEY(tear OR tears OR tore OR torn OR lesion* OR rupture* OR avuls* OR injur* OR repair* OR debride*)) AND PUBYEAR AFT 1989 AND (LIMIT- TO(DOCTYPE, “ar”) OR LIMIT-TO(DOCTYPE, “cp”) OR LIMIT-TO(DOCTYPE, “ip”) OR LIMIT-TO(DOCTYPE, “er”)) AND (LIMIT-TO(EXACTKEYWORD, “Controlled study”) OR LIMIT-TO(EXACTKEYWORD, “Clinical article”) OR LIMIT-TO(EXACTKEYWORD, “Major clinical study”) OR LIMIT-TO(EXACTKEYWORD, “Treatment Outcome”) OR LIMIT-TO(EXACTKEYWORD, “Treatment outcome”) OR LIMIT-TO(EXACTKEYWORD, “Follow up”) OR LIMIT-TO(EXACTKEYWORD, “Follow-Up Studies”) OR LIMIT-TO(EXACTKEYWORD, “Prospective Studies”) OR LIMIT-TO(EXACTKEYWORD, “Comparative study”) OR LIMIT-TO(EXACTKEYWORD, “Clinical trial”) OR LIMIT-TO(EXACTKEYWORD, “Prospective study”))

Table B-8 BIOSIS Previews^®^—Institute for Scientific Information—Thomson Corporation

1926 to 2009 Limits: 1990–2009 | | Searched: 04Feb09 Results: 821
#14 | #13 NOT #10
#13 | #12 NOT #9
#12 | #6 OR #3 Refined by: Major Concepts=(EDUCATION OR SURGERY OR ORTHOPEDICS OR MUSCULAR SYSTEM OR MOVEMENT AND SUPPORT OR METHODS AND TECHNIQUES OR SPORTS MEDICINE OR NUTRITION OR FOODS OR OCCUPATIONAL HEALTH OR NURSING OR PHYSICAL MEDICINE AND REHABILITATION) AND Subject Areas=(SURGERY OR ORTHOPEDICS OR REHABILITATION OR SPORT SCIENCES OR PUBLIC, ENVIRONMENTAL & OCCUPATIONAL HEALTH OR NUTRITION & DIETETICS OR PHARMACOLOGY & PHARMACY)
#11 | #6 OR #3 Refined by: Major Concepts=(EDUCATION OR SURGERY OR ORTHOPEDICS OR MUSCULAR SYSTEM OR MOVEMENT AND SUPPORT OR METHODS AND TECHNIQUES OR SPORTS MEDICINE OR NUTRITION OR FOODS OR OCCUPATIONAL HEALTH OR NURSING OR PHYSICAL MEDICINE AND REHABILITATION)
#10 | SO=(child OR children OR paediatr* OR pediatr* OR peadiatr* OR adoles* OR teen OR teens OR teenage* OR infan* OR baby OR babies OR neonat*) AND Document Type=(Article OR Article Thesis Dissertation OR Book Chapter OR Meeting Paper OR Technical Report OR Thesis Dissertation) AND Taxa Notes=(Humans)
#9 | TI=(child OR children OR paediatr* OR pediatr* OR peadiatr* OR adoles* OR teen OR teens OR teenage* OR infan* OR baby OR babies OR neonat*) AND Document Type=(Article OR Article Thesis Dissertation OR Book Chapter OR Meeting Paper OR Technical Report OR Thesis Dissertation) AND Taxa Notes=(Humans)
#8 | #6 OR #3 AND Document Type=(Article OR Article Thesis Dissertation OR Book Chapter OR Meeting Paper OR Technical Report OR Thesis Dissertation) AND Taxa Notes=(Humans)
#7 | #6 OR #3
#6 | #5 AND #4
#5 | TS=( shoulder or glenohumer*)
#4 | TS=((tendon or tendons or muscle* or muscular) SAME (tear or tears or tore or torn or lesion* or rupture* or avuls* or injur* or repair* or debride*))
#3 | #1 AND #2
#2 | TS=( tear OR tears OR tore OR torn or lesion* OR rupture* OR avuls* OR injur* OR repair* OR debride* OR thickness OR full-thickness OR partial-thickness)
#1 | TS=(supraspinatus OR infraspinatus OR teres minor OR subscapularis OR rotator cuff* OR anterosuperior OR posterosuperior)

Table B-9 PubMed—National Library of Medicine

1950–2009 Limits: added to PubMed in last 2 years or in process | Searched: 16Sep09 Results: 298
#3 #1 0R #2 #2 ((rotator cuff* OR rotator interval* OR supraspinatus OR infraspinatus OR “teres minor” OR subscapularis OR anterosuperior OR posterosuperior) AND (tear OR tears OR tore or torn OR lesion* OR rupture* OR avuls* OR injur* OR repair* OR debride*)) AND ((randomized controlled trial [PTYP] OR drug therapy [SH] OR therapeutic use [SH:NOEXP]) OR random* OR (single blind*) OR (double blind*) OR (trial*) OR (placebo*) OR (research design*) OR (comparative stud*) OR (evaluation stud*) OR (follow up stud*) OR (prospective*) OR (cohort*) OR (case series)) Limits: added to PubMed in the last 2 years, Humans, English, French, German, All Adult: 19+ years #1 ((rotator cuff* OR rotator interval* OR supraspinatus OR infraspinatus OR “teres minor” OR subscapularis OR anterosuperior OR posterosuperior) AND (tear OR tears OR tore or torn OR lesion* OR rupture* OR avuls* OR injur* OR repair* OR debride*)) AND (in process[sb])

Table B-10 Grey Literature Sources

Databases | Searched: 23Jun09
Conference Papers index
Computer Retrieval of Information on Scientific Projects (CRISP) database
Scopus
Websites | Searched: 23Jun09
Health Canada
U.S. Food and Drug Administration
Conference Proceedings Hand Searched | Searched: 24Feb09 | Searched: 22Oct09 **
Arthroscopy Association of North America (AANA) | 2007–2009
AAOS (American Academy of Orthopaedic Surgeons) | 2007–2009
American Physical Therapy Association (APTA) | 2006–2008
American Shoulder and Elbow Surgeons | 2005–2008
American Society of Shoulder and Elbow Therapists | 2004–2008
European Congress of Physical and Rehabilitation | 2008
Medicine | 2009
European Society for Surgery of the Shoulder and the Elbow** | 2006–2008
Mid-America Orthopaedic Association (MAOA)
Clinical Trials Registers | Searched: 23Jun09
ANZCTR (Austrialia NewZeland Clinical Trials Register)
ClinicalStudyResults.org
ClinicalTrials.Gov (National Institutes of Health)
Current Controlled Trials (BioMed Central)
ICTRP (International Clinical Trials Registry Platform Search Portal) (WHO)
Nederlands Trial Register (Dutch Cochrane Centre)