# Expert Panel and Peer Reviewers

## Technical Expert Panel Members

- Judy Chepeha, M.Sc.P.T., Ph.D. (candidate)
- Assistant Professor
- Department of Physical Therapy
- Faculty of Rehabilitation Medicine
- University of Alberta
- Edmonton, AB

- James Chesnutt, M.D.
- Assistant Professor
- Oregon Health Sciences University School of Medicine
- Department of Family Medicine
- Portland, OR

- Philip McClure, P.T., Ph.D.
- Professor
- Arcadia University
- Department of Physical Therapy
- Glenside, PA

- James Mold, M.D., M.P.H.
- Professor
- Director, Research Division
- Department of Family and Preventive Medicine
- University of Oklahoma Health Sciences Center
- Oklahoma City, OK

- David Stutz, M.D., F.A.C.P.
- Clinical Assistant Professor of Medicine
- East Ann Arbor Health and Geriatrics Center
- Ann Arbor, MI

- Amir Qaseem, M.D., Ph.D., M.H.A.
- Senior Medical Associate
- Medical Knowledge and Publishing Division
- American College of Physicians
- Philadelphia, PA

- Ken Yamaguchi, M.D.
- Professor of Orthopaedic Surgery
- Barnes-Jewish Hospital
- Washington University School of Medicine
- St. Louis, MO

## Peer Reviewers

- Judy Chepeha, M.Sc.P.T., Ph.D. (candidate)
- Assistant Professor
- Department of Physical Therapy
- Faculty of Rehabilitation Medicine
- University of Alberta
- Edmonton, AB

- Robert Haralson III, M.D., M.B.A
- Associate Clinical Professor of Orthopaedic Surgery
- University of Tennessee Center for the Health Sciences
- Knoxville, TN

- Joseph Iannotti, M.D., Ph.D.
- Institute Chair
- Orthopaedic and Rheumatologic Institute
- Cleveland, OH

- Philip McClure, P.T., Ph.D.
- Professor
- Department of Physical Therapy
- Arcadia University
- Glenside, PA

- Lori Michener, Ph.D., P.T., S.C.S., A.T.C.
- Assistant Professor
- Department of Physical Therapy
- Virginia Commonwealth Univeristy
- Richmond, VA

- Amir Qaseem, M.D., Ph.D., M.H.A.
- Senior Medical Associate
- Medical Knowledge and Publishing Division
- American College of Physicians
- Philadelphia, PA

- Greg Samsa, Ph.D.
- Associate Professor
- Associate Director, Center for Health Policy Research and Education
- Duke University Medical Center
- Durham, NC

- David Stutz, M.D., F.A.C.P.
- Clinical Assistant Professor of Medicine
- East Ann Arbor Health and Geriatrics Center
- Ann Arbor, MI