# Appendixes

Appendix A Expert Panel and Peer Reviewers

Appendix B Literature Search Strings

Appendix C Review Forms

Appendix D Methodological Quality of Included Studies

Appendix E Evidence Tables

Appendix F List of Excluded Studies and Unobtained Studies