# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Ms. Annabritt Chisholm (article retrieval and data entry), Ms. Liza Bialy (extraction of graphical data, formatting of evidence tables), Dr. Donna M. Dryden (presentation of results), Mr. David Jones (study screening and selection), Ms. Nicola Hooten (study selection) and Mr. Kai Wong (data extraction of prognostic factors). We also thank Ms. Rose Campbell of the Scientific Resource Center, AHRQ Effective Health Care Program, for her assistance with searching the grey literature.

## Technical Expert Panel

- Judy Chepeha, M.Sc.P.T., Ph.D. (candidate)
- University of Alberta
- Edmonton, AB

- James Chesnutt, M.D.
- Oregon Health Sciences University School of Medicine
- Portland, OR

- Philip McClure, P.T., Ph.D.
- Arcadia University
- Glenside, PA

- James Mold, M.D., M.P.H.
- University of Oklahoma Health Sciences Center
- Oklahoma City, OK

- David Stutz, M.D., F.A.C.P.
- East Ann Arbor Health and Geriatrics Center
- Ann Arbor, MI

- Amir Qaseem, M.D., Ph.D., M.H.A.
- American College of Physicians
- Philadelphia, PA

- Ken Yamaguchi, M.D.
- Barnes-Jewish Hospital
- Washington University School of Medicine
- Saint Louis, MO

## AHRQ Contacts

- Stephanie Chang, M.D., M.P.H.
- Acting Director, Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD

- CAPT Karen Lohmann Siegel, P.T., M.A.
- Task Order Officer, Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD