# Abbreviations

AHRQ: Agency of Healthcare Research and Quality
ASES: American Shoulder and Elbow Surgeons
BA: Before-and-after
EPC: Evidence-based Practice Center
CI: Confidence interval
CCT: Controlled clinical trial
CMS: Constant-Murley Score
CT: Computed tomography
DASH: Disabilities of the Arm, Shoulder, and Hand
FSET: Shoulder Elevation Test
IQR: Inter-quartile range
JOA: Japanese Orthopaedic Association
LHB: Long head of biceps
MMLS: Modified mattress locking stitch
MRI: Magnetic resonance imaging
NOQAS: Newcastle-Ottawa Quality Assessment Scales
NSAID: Non-steroidal anti-inflammatory drugs
RC: Rotator cuff
RC-QOL: Rotator Cuff Quality of Life scale
RCR: Rotator cuff repair
RCT: Randomized controlled trial
SF-36: Short Form (36) Health Survey
SLAP: Superior labral from anterior to posterior
SMD: Standardized mean difference
SPADI: Shoulder Pain and Disability Index
SRQ: Shoulder Rating Questionnaire
SSI: Shoulder Strength Index
SSQ: Shoulder Service Questionnaire
SST: Simple Shoulder Test
TEP: Technical expert panel
UAEPC: University of Alberta Evidence-based Practice Center
UCLA: University of California, Los Angeles
PENN: University of Pennsylvania Shoulder Score
VAS: Visual analogue scale
WCB: Workers‘ compensation board
WMD: Weighted mean difference
WORC: Western Ontario Rotator Cuff Index