# Results

## Summary of Studies and Data on In-Hospital, Off-Label rFVIIa Use

Table A in the Executive Summary provides an overall “snapshot” of the data and results for each of the Key Questions, as well as the conclusions of our effectiveness review.

### Summary of Included and Excluded Studies

Our searches for studies on off-label use of rFVIIa identified 5,668 potentially relevant articles of which 1,326 merited full-text review (Figure 2). A total of 74 articles met our inclusion criteria for this review (Table 11). Seventeen of these only met our inclusion criteria for the first part of this report, the section on delineating the breadth of use of rFVIIa and the comparative studies of its use for the clinical indications not covered in Key Questions 2-4. An additional 57 articles met our inclusion criteria for the comparative effectiveness review, of which 14 were RCTs, 24 were comparative observational studies, and 19 were non-comparative reports from registries or cohorts (cohorts limited to those with at least 15 participants). Table 11 gives summary data on the characteristics of included studies. Most of the studies had small to moderate sample sizes, and there was great variability in the doses of rFVIIa administered. Tables 12 and 13 summarize the distribution of included studies by indication, design, and how they are used in this report. While the majority of studies reported data on mortality and thromboembolic events, almost none were powered to distinguish important differences in the rates of these between treatment groups (Appendix C, Appendix Table 2). Instead, most studies used indirect endpoints (e.g., change in hematoma volume or transfusions requirements) as their primary outcomes (Appendix C, Appendix Table 2).

Figure 2 Search results for included studies

“Small sample size” applies only to non-comparative studies with less than 15 patients. “Duplicate publication” includes studies with overlapping patient populations.

Figure 2 shows that a search for studies on off-label use of rFVIIa identified 5,668 potentially relevant articles, of which 1,326 merited full-text review. The figure follows the citations from the 5,668 unique citations to the 1,326 requiring full text review to the 74 unique citations included in the analysis. These 74 are divided at the bottom of the figure into three boxes: RCT has 24, comparative observational has 31, and non-comparative observational has 19.

Table 11 General characteristics of all included studies by clinical indication

Article | Study design | Time period | Country or Region | Setting | Sample size^#^ | | Mean age^*^, years (SD) [Range] | | rFVIIa dose, μg/kg | Manufacturer Sponsorship
| | | | | rFVIIa | UC | rFVIIa | UC
Intracranial hemorrhage
Mayer 2005a23 | RCT | 8/2002–3/2004 | Australia, Europe, Asia, North America | 73 centers | 303 (3 arms) | 96 | 64 – 67 | 68 (12) | 40; 80; 160 | Funding
Mayer 2005b86 | RCT | 8/2001–10/2002 | Australia, Europe, Asia | 14 centers | 36 (6 arms) | 11 | 51 – 68 | 66 (14) | 10; 20; 40; 80; 120; 160 | Funding
Mayer 2006^87^ | RCT | 11/2001–3/2003 | USA | 17 centers | 32 (4 arms) | 8 | 60 – 72 | 67 (13) | 5; 20; 40; 80 | Funding
Mayer 2008^88^ | RCT | 5/2005–2/2007 | Australia, Europe, Asia, North America | 122 centers | 573 (2 arms) | 268 | 65 (14) | 65 (14) | 20; 80 | Funding
Ilyas 2008^89^ | Retrospective comparative | 1/2000–NR | USA | 1 university hospital | 24 | 30 | 76.5 (11) | 76.4 (12.4) | 10–100 | NR
Pickard 2000^90,†^ | Prospective comparative | NR | NR | Multicenter | 5 | 5 | NR | NR | 80; 80+3.5CI; 7.0 CI | Affiliation
Brody 2005^91,†^ | Retrospective comparative | 3/2002–1/2003 | USA | 1 university hospital | 12 | 15 | 71 (13) | 77 (7) | Mean: 4.8 mg SD: 2.1 mg | NR
Hallevi 2008^92,†^ | Retrospective comparative | NR | USA | 1 university hospital | 46 | 148 | 60 [38–87] | 58 [40–80] | 40; 80 | Affiliation
Sutherland 2008^93,†^ | Retrospective non-comparative | 3/2005–12/2006 | Canada | 2 centers | 15 | - | 68^U^ [25–81] | - | Median: 60 Range: 25–81 | Funding
Herbertson 2008^94,†^ (also reports on body trauma) | Retrospective non-comparative | 6/2001–12/2003 | International | Online registry | 20 | - | 7.7 (5.8) | - | Median: 100 Range: 9–393 | Funding
Nussbaum 2009^95,†^ | Retrospective non-comparative | NR | USA | 1 center | 18 | - | 56.8 [42–85] | - | Range: 40–160 | NR
Body trauma
Boffard 2005^96^ | Two RCTs | 3/2002–9/2003 | Australia, Canada, Europe, Israel, South Africa | 32 centers | 139 (2 arms) | 138 (2 arms) | 29 – 33 | 32 – 35 | 200 followed by two 100 | Funding
Rizoli 2006^97^ | Retrospective comparative | 1/2000–1/2005 | Canada | 1 university center | 38 | 204 | 37 | 41 | NR | Affiliation
Spinella 2008^98^ | Retrospective comparative | 12/2003–10/2005 | Iraq | Combat support hospitals | 49 | 75 | NR | NR | 120 | NR
Fox 2009^99^ | Retrospective comparative | 4/2006–8/2007 | Iraq | Combat support hospitals | 41 | 12 | 28 (9) | 24 (10) | 90–120 | None
Dutton 2004^100,†^ | Retrospective comparative | 6/2001–12/2003 | USA | 1 university hospital | 81 | 32–449^ | 41(21) | NR | 50; 100 | Affiliation
Harrison 2005^101,†^ | Retrospective comparative | 2/2003–12/2003 | USA | 1 hospital | 29 | 72 | 41 (21) | 42 (22) | Mean: 60 | NR
Cameron 2007^102,†^ | Retrospective non-comparative | 1/2001–9/2006 | Australia, New Zealand | 53 centers | 108 | - | 38^U^ [11–91] | - | Median: 90 IQR: 78–105 | Funding
Felfernig 2007^103,†^ | Retrospective non-comparative | 9/2000–8/2003 | Europe and Australia | Haemostasi s database | 45 | - | 31 [5–81] | - | Mean: 74 SD: 27 | Funding
Martinowitz 2005^104,†^ | Retrospective non-comparative | NR | Israel | Trauma registry | 36 | - | 19.5 [14–65] | - | Median: 140 Range: 70–540 | Affiliation
Alten 2009^105,†^ | Retrospective non-comparative | 1999–2006 | USA | 1 university center | 15 | - | 7 [IQR 1.1–14] | - | Median: 88 Range: 27–160 | None
Brain trauma
Narayan 2008^106^ | RCT | 8/2004–5/2006 | Canada, Europe, Asia | 38 centers | 61 | 36 | 52 (22) | 51 (20) | 40; 80; 120; 160; 200 | Funding
Stein 2008^107^ | Retrospective comparative | 7/2002–6/2006 | USA | 1 university center | 29 | 34 | 40 (25) | 38 (20) | Range: 8 –140 | Affiliation
Tawil 2008^108,†^ | Retrospective comparative | 1/2004–12/2005 | USA | 1 university center | 31 | 353 | NR | NR | NR | NR
Bartal 2007^109,†^ | Prospective non- comparative | NR | NR | 1 center | 15 | - | 61 (11) | - | Mean: 59 Range: 40–90 | NR
Liver transplantation
Lodge 2005^110^ | RCT | 8/2001–9/2003 | Australia, Europe, North America | 14 centers | 121 (2 arms) | 61 | 53 (10) | 52 (12) | 60; 120 | Affiliation
Planinsic 2005^111^ | RCT | 2/2000–9/2000 | Europe, USA | 9 centers | 64 (3 arms) | 19 | 49 – 52 | 50 (11) | 20; 40; 80 | Affiliation
Pugliese 2007^112^ | RCT | 11/2003–7/2004 | Italy | 1 university center | 10 | 10 | NR | NR | 40 | NR
Liu 2009^113^ | RCT | 3/2003–7/2006 | China | 1 university center | 14 | 14 | 51.9 [36–54] | 47.5 [41–65] | 70–80 | NR
Hendriks 2001^114^ | Prospective comparative | 12/1998–9/1999 | Netherlands | 1 center | 6 | 6 | 43^U^ [37–61] | 48^U^ [34–63] | 80 | Affiliation
De Gasperi 2005^115,†^ | Retrospective comparative | 2/2003 | Italy | 1 center | 6 | 6 | 45 (4) | 47 (9) | 20; 40 | NR
Kalicinski 2005^116,†^ | Retrospective comparative | NR | Poland | 1 center | 28 | 61 | 13 (4) | 11 (6) | Mean: 52 Range: 30–100 | NR
Niemann 2006^117,†^ | Retrospective comparative | 2000–2004 | USA | 1 university center | 11 | 11 | 48 (15) | 41 (17) | Mean: 58 SD: 18 | NR
Adult cardiac surgery
Diprose 2005^118^ | RCT | NR | UK | 1 center | 10 | 10 | 70^U^ [64–77]^I^ | 63^U^ [59–66]^I^ | 90 | Funding
Gill 2009^119^ | RCT | 8/2004–11/2007 | 13 countries | 30 centers | 104 | 68 | 63–68 | 62 (16) | 40; 80 | Funding
Karkouti 2005^120^ | Retrospective comparative | 11/2002–2/2004 | Canada | 1 center | 51 | 51 | 56 | 59 | Mean: 60 SD: 13 | None
Gelsomino 2008^121^ | Retrospective comparative | 9/2005–6/2007 | Italy | 1 center | 40 | 40 | 70 (9) | 76 (10) | Median: 19 IQR: 6–16 | NR
Tritapepe 2007^122^ | Retrospective comparative | 1/2003–12/2005 | Italy | 1 center | 23 | 23 | 62 (9) | 62 (9) | Mean: 82 | NR
von Heymann 2005^123^ | Retrospective comparative | 6/2000–3/2003 | NR | 1 center | 24 | 24 | 65 | 65 | 60–80 with possible repeat doses | NR
Bowman 2008^124,†^ | Retrospective comparative | 1/2001–12/2006 | USA | 1 center | 36 | 385 | 58 (15) | NR | Mean: 100 | NR
Trowbridge 2009^125,†^ | Prospective comparative | NR | USA | 1 center | 17 | 187 | 70 (9) | 67 (11) | NR | None
Filsoufi 2006^126,†^ | Retrospective non-comparative | 6/2003–12/2005 | USA | 1 center | 17 | - | 63 (15) | - | Mean: 103 SD: 30 | NR
Gandhi 2007^127,†^ | Retrospective non-comparative | 1/2003–8/2005 | USA | 1 center | 17 | - | 53[38–64] | - | Mean: 78 Range: 24–189 | NR
Hyllner 2005^128,†^ | Retrospective non-comparative | 1/2004–8/2004 | Sweden | 1 center | 24 | - | 60^U^[34–82] | - | Mean: 72 | NR
McCall 2006^129,†^ | Retrospective non-comparative | 12/2002–8/2005 | Australia | 1 center | 53 | - | 68[55–75]^I^ | - | Mean: 90 SD: 15 | Affiliation
Raivio 2005^130,†^ | Retrospective non-comparative | 6/2002–10/2004 | Finland | 1 center | 16 | - | 60 (15) | - | Mean: 65 Range: 24–192 | NR
Aggarwal 2004^131,†^ | Retrospective non-comparative | 6/2001–6/2003 | USA | 1 center | 24 | - | 65^U^[26–85] | - | 90 | NR
Karkouti 2008^132,†^ | Retrospective non-comparative | 1/2003–12/2006 | Canada | 18 centers | 503 | - | 62 (15) | - | Median: 62 IQR: 40–89 | Funding
Dunkley 2008^133,†^ | Retrospective non-comparative | 1/2001–9/2006 | Australia, New Zealand | 21 centers | 293 | - | 63 (15) | - | Median: 92 IQR: 82–103 | Funding
Bruckner 2009^134,†^ (2 doses) | Retrospective non-comparative | 1/2004–11/2006 | USA | 1 center | 32 30 | - - | 51 (17) 51 (17) | - - | Range: 10–20 Range: 30–70 | NR
Masud 2009^135,†^ | Retrospective non-comparative | 1/2004–9/2005 | USA | 1 university hospital | 93 | - | 60.6 (14.5) | - | Mean: 56.2 SD: 26.5 | Affiliation
Hsia 2009^136,†^ | Retrospective non-comparative | 1/2003–6/2007 | United Kingdom | 1 center | 23 | - | 55 [18–84] | - | NR | NR
Pediatric cardiac surgery
Ekert 2006^137^ | RCT | NR | Australia | 1 center | 40 | 35 | 4 months | 4 months | Mean: 63 | NR
Agarwal 2007^138,†^ | Retrospective comparative | 1/2000–12/2004 | USA | 1 center | 24 | 22 | 10 days [4–3285] | 7 days [2–240] | Mean: 43 SD: 23 | None
Tobias 2004^139,†^ | Prospective comparative | 1/2003 | Dominican Republic | 1 center | 9 | 8 | 9 (4) | 10 (3) | 90 | Affiliation
Niles 2008^140,†^ | Retrospective comparative | 2004–2006 | USA | 1 center | 15 | 15 | 60 days (99); 5293 days (471)^**^ | 16 days (19); 4531 days (2758)^**^ | Range: 76–282; 26–956^**^ | None
Prostatectomy
Friederich 2003^141^ | RCT | NR | Netherlands | 1 center | 24 (2 arms) | 12 | 61 – 64 | 63 (8) | 20; 40 | Affiliation
Other liver disease
Jeffers 2002^142^ | Non-comparative RCT^#^ | NR | USA | 3 centers | 71 (5 arms) | - | 46 – 52 | - | 5; 20; 80; 120 | Affiliation
Bosch 2004^143^ | RCT | 4/2001–4/2002 | Europe | 26 centers | 121 | 121 | 54 (11) | 53 (12) | 800 | Funding
Shao 2006^144^ | RCT | 7/2001–12/2002 | China, Taiwan, Thailand | 7 centers | 155(2 arms) | 76 | 53 – 54 | 49^U^ [30–75] | 50; 100 | Affiliation
Bosch 2008^145^ | RCT | 4/2004–8/2006 | 12 countries in Europe and Asia | 31 centers | 170 (2 arms) | 86 | 55 (12) | 54 (10) | 300; 600 | Funding
Shami 2003^146^ | Retrospective comparative | 12/1999-NR | USA | 1 center | 7 | 8 | 34 [16–64] | 28 [7–45] | 40; 80 | NR
Obstetrics/gynecology
Ahonen 2007^147^ | Retrospective comparative | NR | Finland | 1 center | 26 | 22 | 33 (4) | 35 (4) | Mean: 100 SD: 14 | NR
Hossain 2007^148^ | Retrospective comparative | 3/2005–10/2006 | Pakistan | 1 center | 18 | 16 | 29^U^ [26–32]^I^ | 29^U^ [26–30]^I^ | 70 | NR
McMorrow 2008^149^ | Retrospective comparative | 2003–2006 | Ireland | 1 center | 6 | 6 | 34 (3) | 31 (5) | NR | NR
Hematology/oncology
Chuansumrit 2005^150^ | RCT | 7/2001–12/2002 | Thailand, Philippines | 5 centers | 16 | 9 | 9 (4) | 11 (3) | 100; 200 | Funding
Pihusch 2005^151^ | RCT | 4/2001–10/2003 | Australia, Europe | 21 centers | 77 (3 arms) | 23 | 36 – 38 | 39^U^ [18–64] | 280; 560; 1120 | Funding
Gupta 2007^152^ | Retrospective comparative | 1/2002–12/2004 | USA | 1 center | 24 | 63 | NR | NR | NR | None
Other surgery
Lodge 2005^153^ | RCT | 1/2001–1/2002 | France, Spain, Germany, UK | 13 centers | 122 (2 arms) | 63 | 56 (13) | 56 (14) | 20; 80 | Funding
Raobaikady 2005^154^ | RCT | 8/2002–3/2004 | UK | 1 center | 24 | 24 | 44^U^ [18–57] | 38^U^ [18–57] | 90; 180 | Funding
Johansson 2007^155^ | RCT | 6/2001–12/2003 | Denmark | 1 center | 9 | 9 | 54^U^ [22–85] | 38^U^ [19–81] | 80 | Funding
Sachs 2007^156^ | RCT | 7/2004–2/2006 | USA | 13 centers | 36 (3 arms) | 13 | 45 – 46 | 50 [17–65] | 90; 180; 360 | Funding
Roitberg 2005^157^ | Retrospective comparative | 7/2001–11/2002 | USA | 1 center | 29 | 24 | 60 | 67 | NR | NR
Kolban 2006^158^ | Retrospective comparative | 2000–2003 | Poland | 1 center | 26 | 26 | 17 [10–22] | 16 [12–19] | Mean: 23 | NR

† For Key Question 2–4 indications, these studies did not meet inclusion criteria for the comparative effectiveness analyses due to poor quality (Table 14) (so are included in qualitative sensitivity discussions within their respective indication and for the harms analyses) or because they were non-comparative studies (so are included only in the harms analyses).

* For RCTs with more than one dosing arm, the range of mean ages of each dosing arm is presented.

** Patients were divided into 2 groups: those <30 kg (N=11) and those>30 kg (N=4), respectively;

# The sample size presented is the largest sample size the study reported for each treatment arm. Sample size may vary for each outcome reported within a study.

^ Dutton 2004^100^ has multiple control groups. The range of sample sizes is presented.

# Jeffers 2002^142^ did not have a usual care (i.e. placebo) group, but randomized patients in a double-blind fashion to doses of 5, 20, 80, and 120 ug/kg rFVIIa.

U Median;

I IQR;

UC=usual care; NR=not reported; IQR=interquartile range;

Funding=Novo Nordisk funded the study or an author or statistician was an employee of Novo Nordisk; Affiliation=an author belonged to the Novo Nordisk speakers bureau, or received fees, payments, or funding for other projects or work from Novo Nordisk.

Table 12 Clinical indication and study type of included studies

Clinical Indication | Number of studies N (percent)
| Total N=74 | RCT N=24 | Comparative observational N=31 | Non-comparative observational N=19
Key Question 1 Indications
Other liver disease | 5 | 4 (17) | 1 (3) | NC
Obstetrics/gynecology | 3 | 0 (0) | 3 (10) | NC
Hematology/oncology | 3 | 2 (8) | 1 (3) | NC
Other surgery | 6 | 4 (17) | 2 (7) | NC
Key Questions 2-4 Indications
Intracranial hemorrhage | 11 | 4 (17) | 4 (13) | 3 (16)
Body trauma | 11 | 1 (4) | 5 (16) | 2 (11)
Brain trauma | 4 | 1 (4) | 2 (7) | 1 (5)
Liver transplantation | 8 | 4 (17) | 4 (13) | 0
Adult cardiac surgery | 19 | 2 (8) | 6 (19) | 11 (58)
Pediatric cardiac surgery | 4 | 1 (4) | 3 (10) | 0
Prostatectomy | 1 | 1 (4) | 0 (0) | 0

Note: Data from non-comparative observational studies were used to analyze harms associated with rFVIIa use.

NC=not collected

Table 13 Study categories by study design and use in analysis

Study Category | | Use in this Comparative Effectiveness Review
| | Survey of Existing Research (KQ1) | Evaluation of Effectiveness (KQ2-4) | | Evaluation of Harms (KQ2–4)
| | Survey of Existing Research (KQ1) | Used for Systematic Review | Used for Meta-Analyses | Evaluation of Harms (KQ2–4)
Randomized clinical trials | Five key indications | 14 | 14 | 6^*^ | 14
Randomized clinical trials | Other indications | 10 | | Outside Project Scope^†^
Comparative observational studies | Five key indications and good quality | 2 | 2 | 2^*^ | 2
Comparative observational studies | Five key indications and fair quality | 8 | 9 | Insufficient Quality | 9
Comparative observational studies | Five key indications and poor quality | 14 | Insufficient Quality for Detailed Review^**^ | | 14
Comparative observational studies | Other indications | 7 | | Outside Project Scope^†^
Non-comparative observational studies | Five key indications and ≥ 15 patients | 19 | Contributes No Information | | 19
Non-comparative observational studies | Other indications or < 15 patients | | Outside Projects Scope^†^

* For the indications of intracranial hemorrhage and adult cardiac surgery only.

** Poor quality comparative observational studies were not reviewed in detail for the comparative effectiveness part of the report, but their data were included in the outcomes tables so that qualitative sensitivity analyses could be performed by placing their findings in the context of the findings of the higher quality studies.

† Because certain study categories fell outside of the project scope, they were not used for the indicated evaluations in the comparative effectiveness review.

#### Unpublished Studies in the Grey Literature

Studies identified via online databases where clinical trials are registered but without a subsequent publication. Our search of online resources (e.g., ClinicalTrials.gov or the manufacturer’s website) for ongoing or completed RCTs that were registered on an online database identified 29 trials with and without subsequent publications, either in the form of an abstract or published article (Appendix Table 4). Of the completed RCTs on Key Questions 2-4, 11 of 16 (69%) have been published: 71% (5/7) on intracranial hemorrhage, 50% (2/4) on body trauma, 50% (1/2) on adult cardiac surgery, and 100% on brain trauma (1/1), liver transplantation (1/1), and pediatric cardiac surgery (1/1). Three of five of the unpublished studies (one on intracranial hemorrhage and two in body trauma) were sponsored by the manufacturer.

Abstracts identified without subsequent publications. Our literature search identified 76 abstracts for which we were unable to find a subsequent full publication. All but three of these were excluded based on our exclusion criteria. Of these three abstracts, one described an RCT of rFVIIa use in liver transplantation with 12 patients in each of the treatment and placebo arms.83 The remaining two abstracts described case series, containing 17 and 24 adult cardiac surgery patients, respectively.84,85

Non-English language studies. We found 134 articles written in 15 different languages: 45 potentially addressing Key Questions 2-4 indications (intracranial hemorrhage, body and brain trauma, liver transplantation, adult and pediatric cardiac surgery, and prostatectomy) and 89 addressing other indications. Because we were not in a position to translate all of the different languages, we relied on English language abstracts and information in indexing databases to determine if articles met our inclusion criteria. Of the 45 articles on Key Questions 2-4 indications, 37 (82%) were excluded because they met other exclusion criteria. The remaining 8 (17%) were excluded solely on the basis of being published in a non-English language (Appendix Table 5). Of these, two were comparative studies. One was an RCT on adults who underwent cardiac surgery in China (11 patients each in the rFVIIa and placebo groups); this article was used for sensitivity analyses in the adult cardiac surgery section of Key Question 3. The other was a comparative cohort study of brain trauma with seven patients in the treatment group. The remaining six articles were case series (range of 15 to 34 patients). Of the 89 articles on other indications, 83 (93%) were excluded because they met other exclusion criteria; of the remaining six that were excluded on the basis of non-English language, four were case series, one was a comparative observational study and for one the study design was unclear.

### Quality of Studies Included in Key Questions 2-4

The assigned grades of the two independent assessors never differed by more than one level of the categorical grading schema (good, fair, or poor). Of the RCTs assessed, there was initial agreement on the grade assignment in 13 of 14 (92%). Of the comparative observational studies assessed, there was initial agreement on the grade assignment in 22 of 24 (91%). All disagreements related to whether to categorize the given study as “poor” or “fair.” These were successfully resolved by discussion.

Overall, the published literature contained relatively few fair or good quality comparative studies within any given clinical indication (Table 14). Three of 14 (21 percent) RCTs were determined to be poor quality. In all cases, there was little or no description of the methods of randomization or allocation concealment or of the blinding of subjects, providers, or outcomes assessors, along with other methodologic shortcomings. Poor quality RCTs were still included in the evaluations of effectiveness for each clinical indication. In contrast, 14 of 24 (58 percent) comparative observational studies were judged to be of poor quality and were not included in the comparative effectiveness review but were used for qualitative sensitivity testing, and their data on harm (in the patients who received rFVIIa) were included in the results section on non-comparative evidence of harm. In all cases where comparative observational studies were determined to be of poor quality, there were study designs that were inappropriate for generating comparability of groups, inadequate methods to control for confounding, lack of blinding of outcomes assessors, or differential follow-up/high rates of missing data, among other methodological shortcomings.

Table 14 Study quality assessments

Study reference | Study type | Quality | Study is subsequently included and reviewed in detail in the following
| | | Comparative effectiveness analyses | Harms analyses
Intracranial hemorrhage
Mayer 2005a23 | RCT | Good | X | X
Mayer 2005b86 | RCT | Fair | X | X
Mayer 2006^87^ | RCT | Fair | X | X
Mayer 2008^88^ | RCT | Good | X | X
Ilyas 2008^89^ | Comparative observational | Fair | X | X
Hallevi 2008^92^ | Comparative observational | Poor^*^ | | X
Pickard 2000^90^ | Comparative observational | Poor^*^ | | X
Brody 2005^91^ | Comparative observational | Poor^*^ | | X
Body trauma
Boffard 2005^96^ | RCT | Fair | X | X
Rizoli 2006^97^ | Comparative observational | Fair | X | X
Spinella 2008^98^ | Comparative observational | Fair | X | X
Fox 2009^99^ | Comparative observational | Fair | X | X
Dutton 2004^100^ | Comparative observational | Poor^*^ | | X
Harrison 2005^101^ | Comparative observational | Poor^*^ | | X
Brain trauma
Narayan 2008^106^ | RCT | Fair | X | X
Stein 2008^107^ | Comparative observational | Fair^†^ | X | X
Tawil 2008^108^ | Comparative observational | Poor^*^ | | X
Liver transplantation
Lodge 2005^110^ | RCT | Fair | X | X
Planinsic 2005^111^ | RCT | Fair | X | X
Pugliese 2007^112^ | RCT | Poor | X | X
Liu 2009^113^ | RCT | Poor | X | X
Hendriks 2001^114^ | Comparative observational | Fair | X | X
Kalicinski 2005^116^ | Comparative observational | Poor^*^ | | X
Neimann 2006^117^ | Comparative observational | Poor^*^ | | X
De Gasperi 2005^115^ | Comparative observational | Poor^*^ | | X
Adult cardiac surgery
Gill 2009^119^ | RCT | Good | X | X
Diprose 2005^118^ | RCT | Fair | X | X
Gelsomino 2008^121^ | Comparative observational | Good | X | X
Karkouti 2005^120^ | Comparative observational | Good | X | X
Von Heymann 2005^123^ | Comparative observational | Fair | X | X
Tritapepe 2007^122^ | Comparative observational | Fair | X | X
Bowman 2008^124^ | Comparative observational | Poor^*^ | | X
Trowbridge 2008^125^ | Comparative observational | Poor^*^ | | X
Pediatric cardiac surgery
Ekert 2006^137^ | RCT | Poor | X | X
Agarwal 2007^138^ | Comparative observational | Poor^*^ | | X
Tobias 2004^139^ | Comparative observational | Poor^*^ | | X
Niles 2008^140^ | Comparative observational | Poor^*^ | | X
Prostatectomy
Friederich 2003^141^ | RCT | Fair | X | X

RCT=randomized controlled trial;

* Poor quality comparative observational studies were not included in the comparative effectiveness analyses, but their data were included in the outcomes tables so that qualitative sensitivity analyses could be performed by placing their findings in the context of the findings of the higher quality studies.

† This study was deemed “fair” for the data on patients with isolated TBI only, and these data were included in the comparative effectiveness analysis.

### Summary of Data from the Premier Database

The search of the Premier database identified nationally representative information on patterns of inpatient use of rFVIIa from 235 U.S. hospitals of the 615 hospitals in the database (38 percent). From 2000 through 2008, the database identified a total of 12,644 hospital cases (any use during a patient hospitalization) where rFVIIa use was reported. Our results indicate d that real-world application of rFVIIa was concentrated among three of the key clinical indications that are the focus of this report: intracranial hemorrhage, body trauma, and cardiac surgery. Application to these indications encompassed 55 percent of hospital cases of rFVIIa use from 2000 to 2008, and 68 percent of hospital casesin 2008 alone. There was variability in use for other indications, as discussed below under Key Question 1.

## Key Question 1. Overview of off-label rFVIIa use in-hospital and comparative studies

### Overview of Trends in Factor VIIa Use in United States Hospitals, 2000–2008

The majority of use of rFVIIa occurs in the outpatient setting, and the majority of outpatient use is for on-label indications related to hemophilia. Nonetheless, in-hospital U.S. sales of rFVIIa in 2007 are estimated to have been $138.5 million.8 Data from the Premier sample of 615 U.S. hospitals provide nationally representative information (via weighted estimates) about patterns of inpatient rFVIIa use. From 2000 through 2008, there were an estimated 73,747 hospital discharges in the U.S. where rFVIIa use was reported. Over this period, there was growth in in-hospital use of rFVIIa where the unit of analysis was a “case” of use (any application during a patient hospitalization). While most cases were limited to hemophilia and several related hematologic conditions from 2000–2001, such use has leveled over time. In contrast, recent years have witnessed more frequent off-label in-hospital cases. Off-label in-hospital rFVIIa use was estimated to be 125 cases in 2000, underwent a moderate increase until 2005 when use became more frequent and was estimated to be 11,057 cases, and by 2008 was estimated to be 17,813 cases (97 percent of all of the estimated 18,311 in-hospital cases), although the rate of increase may be plateauing for many indications(Figures 3 and 4). The most prominent and rapidly increasing indications are cardiac surgery and traumatic bleeding, with cardiac surgery demonstrating the most sustained increase in use. More modest use is associated with non-traumatic intracranial hemorrhage, liver disease, gastrointestinal bleeding, and aortic aneurysm (Table 15 and Figures 3 and 4).

Figure 3 Growth of in-hospital, off-label vs. on-label uses of rFVIIa in Premier database

Figure 3 depicts the growth of in-hospital, off-label uses of rFVIIa in Premier database for hemophilia, ICH, trauma, liver transplant, CV surgery, prostatectomy, and other uses. The x axis starts at 0 hospitalizations and ends at 8,000. The y axis shows years from 2000 to 2008. The line graph shows the most change in all other off label uses.

Figure 4 Growth of in-hospital, off-label vs. on-label uses of rFVIIa in Premier database, 2000–2008

Figures 3 and 4 present similar information. However, “all other” in Figure 4 includes liver transplantation and prostatectomy, as well as all of the other indications.

Figure 4 depicts the growth of in-hospital, off-label vs. on-label uses of rFVIIa in Premier database from 2000-2008. It examines the following hospitalizations: hemophilia, ICH, trauma, CV surgery and all other off-label use. It shows how over time cases of use for hemophilia increased 3.7 fold since 2000 but then plateaued; how CV surgery was the most frequent and most rapidly rising indication, although the frequency level may be leveling off; how use of rFVIIa for trauma grew continuously between 2002 and 2007 but leveled off in 2008; and how ICH reached sizable scale only in 2005, growing rapidly until 2008. Figures 3 and 4 present similar information. However, “all other” in Figure 4 includes liver transplantation and prostatectomy, as well as all of the other indications.

Table 15 Summary data from Premier database according to clinical indication for rFVIIa use

Clinical Indication | Hospital Discharges, 2000–2008 (Sample=12644) | | Hospital Discharges, 2008 (Sample=3245)
Clinical Indication | Number | Percentage of Total | Number | Percentage of Total
All patients treated with rFVIIa | 73747 | 100.0 | 18311 | 100.0
Indications that are the focus of our effectiveness evaluation
Intracranial hemorrhage | 7760 | 10.5 | 2008 | 11.0
Body trauma | 11689 | 15.9 | 3214 | 17.6
Brain trauma | 7158 | 9.7 | 2033 | 11.1
Liver transplantation | 132 | 0.2 | 58 | 0.3
Adult cardiac surgery | 12086 | 16.4 | 4862 | 26.6
Pediatric cardiac surgery | 1684 | 2.3 | 387 | 2.1
Prostatectomy | 120 | 0.2 | 0 | 0.0
Total | 40629 | 55.1 | 12562 | 68.6
Other off-label indications
Liver Biopsy/Resection | 867 | 1.2 | 122 | 0.7
Variceal Bleeding | 897 | 1.2 | 235 | 1.3
Other Liver Disease | 2451 | 3.3 | 539 | 3.0
Neurosurgery | 500 | 0.7 | 108 | 0.6
Obstetrical Hemorrhage | 672 | 0.9 | 220 | 1.2
Cancer/Stem Cell Transplant | 1094 | 1.5 | 138 | 0.8
Other Gastrointestinal Bleeding | 3881 | 5.3 | 713 | 3.9
Neonatal | 729 | 1.0 | 135 | 0.7
Pulmonary Hemorrhage | 1119 | 1.5 | 275 | 1.5
Aortic Aneurysm | 1216 | 1.7 | 306 | 1.7
Other Vascular | 1530 | 2.1 | 390 | 2.1
Primary Clotting Disorders | 4104 | 5.6 | 792 | 4.3
Secondary Clotting Disorders | 3744 | 5.1 | 766 | 4.2
Other Procedures | 3867 | 5.2 | 407 | 2.2
Other Diagnoses | 3346 | 4.5 | 117 | 0.6
Total | 30017 | 40.7 | 5263 | 28.7
FDA approved indication
Hemophilia A and B | 3121 | 4.2 | 498 | 2.7

* Weighted to be nationally representative

Hemophilia A and B, and related conditions. Initial use of rFVIIa was limited to the FDA-approved indications, including hemophilia A and B, as well as related conditions, such as other factor deficiencies, von Willebrand Disease and Glanzmann’s thrombasthenia. Over time, cases of use for hemophilia A and B increased 3.7-fold since 2000 (131 during 2000 versus 498 during 2008) but then plateaued, while there has be en a 7.4-fold increase in cases for related conditions (107 during 2000 versus 792 during in 2008). These two groups remained the most frequent cluster of indications from 2000 through 2003. Together, they accounted for 10 percent of all reported cases, but their representation among indications for in-hospital use fell over time, from 92.9 percent of cases in 2000 to just 7.1 percent of cases in 2008 (498 cases). Hemophilia A and B, by themselves, accounted for only 2.7 percent of cases in 2008.

Cardiovascular surgery. rFVIIa use in cardiac surgery was initially observed in 2002, and by 2008 was the most frequent (29% of cases, along with trauma) and most rapidly rising indication. Use in pediatric cardiac surgery, largely for rep air of congenital anomalies, increased only modestly, accounting for 2.3 percent of cases overall and 2.1 percent in 2008. On the other hand, rFVIIa use in adult cardiac surgery, largely for aortic valve, mitral valve and CABG procedures, rapidly increased over time, accounting for 16.4 percent of cases overall and 2 6.6 percent in 2008. By 2008, use in all cardiac surgery (5,250 cases) was nearly four times higher than in 2005 ( 1,375 cases), indicating rapid adoption of rFVIIa use for this indication, although the frequency of use may be leveling off.

Trauma. Traumatic bleeding represents the first area of major rFVIIa usage beyond hemophilia and related conditions. Sizable use began in 2002 and it remained the dominant indication for off-labelin-hospital cases of rFVIIa use until it was matched by cardiac surgery (at 29% of casess) in 2008. Use of rFVIIa for trauma grew continuously between 2002 and 2007 but leveled off in 2008, the first indication of stabilization in usage patterns. Nevertheless, trauma other than brain trauma remained the second most frequent indication for rFVIIa use and accounted for 15.9 percent of overall 2000–08 cases and 17.6 percent of cases in 2008 (3,214 cases). Use in brain trauma, particularly traumatic subdural hematoma, grew over time to constitute 9.7 percent of overall 2000–08 cases and 11.1 percent of cases in 2008 (2,033 cases).

Intracranial hemorrhage. rFVIIa use in non-traumatic intracranial hemorrhage, particularly intracerebral hemorrhage(ICH), reached sizable scale only in 2005. Use for this indication then grew rapidly, with cases in 2008 (2,005 cases) nearly 8-fold higher than was reported in 2004 (253 cases). Notably, however, use of rFVIIa for intracranial hemorrhage fell slightly from 2007 to 2008. Intracranial hemorrhage accounted for 10.5 percent of rFVIIa cases overall and 11 percent in 2008.

Liver disease. A range of indications related to liver disease collectively constitute another cluster of modest rFVIIa use. Overall, these uses accounted for six percent of all cases, including liver transplant (0.2 percent), liver biopsy (1.2 percent), variceal bleeding (1.2 percent), and other liver indications (3.3 percent). There were 954 cases estimated for 2008, which was down from a peak of 1023 cases in 2007.

Other conditions. Other gastrointestinal bleeding, particularly hemorrhage from the colon, accounted for 5.3 percent of cases overall. Management of aortic aneurysm, in the presence and absence of surgical intervention, contributed modestly and stably to overall use of rFVIIa, with 1.7 percent of cases overall and in 2008. Other vascular surgery accounted for 2.1 percent of cases overall and in 2008. A range of other conditions contributed minimally to rFVIIa use, including pulmonary indications (1.5 percent of cases overall, particularly biopsy and lung transplant), cancer-related conditions ( 1.5 percent, particularly leukemia), neonatal use (1.0 percent), and obstetrical conditions( 0.9 percent, particularly post-partum hemorrhage). A variety of other hematologic conditions were associated with rFVIIa use (5.1 percent of cases overall, 4.2 percent in 2008), particularly secondary thrombocytopenias and complications of warfarin anticoagulation. rFVIIa use also was associated with a wide variety of other surgical procedures, although none are individually prominent. Together, these procedures account for 5.3 percent of cases overall and 2.2 percent in 2008. Brain surgery, as the most frequent procedure among these, constituted 0.6 percent of cases overall and 0.7 percent in 2008. Of note, despite its prominence in this report, prostate surgery was an exceedingly rare indication for rFVIIa use, comprising only an estimated 120 cases nationally from 2000 through 2008 with no cases noted in 2008. As a whole, procedural use of rFVIIa declined between 2006 and 2008.

Age and gender distribution. Age and gender distribution. Overall, about 26 percent of in-hospital rFVIIa cases were in patients under the age of 45 years of age. Consistent with the growth of off-label indications, there was a significant increase in the mean age of patients from 3 years in 2000 to 59 years in 2008. The age distribution of rFVIIa use varied enormously by indication. Use for Hemophilia A and B was predominantly in patients 25 years of age and younger (73 percent). At the other extreme, 58 percent of rFVIIa cases in intracranial hemorrhage were for patients 65 years of age and older, with 36 percent in those 75 years and older. Beyond intracranial hemorrhage, other conditions where use in the elderly (>65 years) was prominent included aortic aneurysm (82 percent of cases), prostatectomy (66 percent), brain trauma (58 percent), adult cardiac surgery (57 percent), and gastrointestinal bleeding (57 percent) (Table 16).

Table 16 Mean age and disposition of patients who received rFVIIa during hospitalizations from 2000–2008

Indication | Total number of hospitalizations | Mean age | Disposition
Indication | Total number of hospitalizations | Mean age | Died^†^ (percent) | Hospice (percent) | Other^‡^ (percent) | Home (percent)
Hemophilia | 3121 | 26.0 | 3.8 | 0.8 | 10.6 | 84.8
Intracranial hemorrhage (ICH) | 7755 | 64.7 | 34.4 | 5.8 | 43.9 | 15.9
Body trauma | 11689 | 52.8 | 33.1 | 1.4 | 35.3 | 30.2
Brain trauma | 7158 | 63.3 | 33.1 | 4.8 | 39.4 | 22.7
Liver transplantation | 132 | 51.8 | 38.1 | 0.0 | 14.3 | 47.6
Adult cardiac surgery | 12086 | 65.3 | 23.3 | 0.3 | 28.2 | 48.2
Pediatric cardiac surgery | 1684 | 2.6 | 21.7 | 0.5 | 4.5 | 73.3
Prostatectomy | 120 | 68.9 | 0.0 | 12.3 | 6.8 | 80.9
Other primary hematologic | 4104 | 48.8 | 16.8 | 2.1 | 23.9 | 57.2
Other secondary hematologic | 3744 | 55.8 | 30.1 | 2.7 | 25.9 | 41.3
Liver biopsy | 867 | 49.3 | 35.9 | 6.2 | 12.7 | 45.2
Varices | 897 | 52.4 | 39.0 | 2.2 | 26.6 | 32.2
Other liver disease | 2451 | 53.3 | 40.4 | 5.1 | 22.6 | 31.9
Other gastrointestinal bleed | 3881 | 63.7 | 29.7 | 3.3 | 27.5 | 39.5
Other vascular | 1530 | 55.6 | 38.5 | 2.5 | 27.8 | 31.2
Aortic aneurysm | 1216 | 72.8 | 54.4 | 1.1 | 25.5 | 19.0
Pulmonary | 1119 | 53.4 | 24.5 | 1.8 | 27.9 | 45.8
Cancer | 1094 | 55.6 | 13.8 | 4.7 | 14.1 | 67.4
Neonatal | 729 | 0.01 | 46.7 | 0.9 | 14.1 | 38.3
Obstetric | 672 | 30.6 | 14.6 | 0.0 | 7.8 | 77.6
Other procedure | 4351 | 57.6 | 9.4 | 0.9 | 25.1 | 64.6
Other diagnosis | 3346 | 59.2 | 5.8 | 0.3 | 17.2 | 76.7
Total | 73746 | | 26.5 | 2.3 | 28.5 | 42.7

† In-hospital deaths.

‡ Inter-hospital transfers and transfers to skilled nursing and rehabilitation facilities.

In-hospital use of rFVIIa in the early 2000s was almost exclusively in males (98 percent of cases in 2000), as is expected from the inheritance pattern of Hemophilia A and B. Given the expansion of use into off-label indications this differential has diminished over time. A male predominance persisted (63 percent in 2008) largely due to a preponderance of men treated for the most frequent indications of adult cardiac surgery (68 percent) and body trauma (68 percent).

In-hospital mortality. Overall, in-hospital mortality was substantial among patients receiving rFVIIa, with 27 percent of patients dying while hospitalized (Table 16). Only 43 percent of patients were discharged directly home. A small percentage of patients receiving rFVIIa were discharged to hospice (2 percent). Most of the remaining patients were transferred to other facilities, including nursing homes, rehabilitation hospitals, and other acute care facilities (29 percent). Mortality increased substantially over time from five percent in 2000 to a peak of 31 percent in 2004, before it declined to 27 percent in 2008. Across all of the reported indications, mortality was infrequent only for rFVIIa use in Hemophilia A and B (4 percent). The most substantial mortality rates were associated with aortic aneurysm (54 percent), neonatal use (47 percent), variceal bleeding (39 percent), other liver disease (40 percent), liver biopsy (36 percent), vascular procedures (39 percent), intracranial hemorrhage (34 percent), brain trauma (33 percent), body trauma (33 percent), and gastrointestinal bleeding (30 percent). The populations receiving rFVIIa for adult and pediatric cardiac surgery experienced 23 and 22 percent in-hospital mortality rates, respectively, in contrast to patients undergoing prostatectomy who had a mortality rate of zero.

Hospital characteristics. rFVIIa use was reported in 235 of the 615 hospitals (38 percent) represented in the Premier database. Most of these hospitals had minimal and sporadic use of rFVIIa, whereas the ten hospitals with the highest number of uses by discharge accounted for 46 percent of all rFVIIa cases of use. These same hospitals had a particularly large share of pediatric cardiac surgery. They had a much smaller share of adult cardiac surgery, consistent with the wider diffusion of rFVIIa use to other hospitals for this indication. A majority of rFVIIa use occured in non-teaching hospitals (68 percent of cases). Over time, the proportion of use of rFVIIa in non-teaching hospitals grew from just 10.6 percent of cases in 2000 to a peak of 73 percent in 2005 and a similar but lower proportion of 67 percent in 2008. The majority of cases of rFVIIa use for each indication occured in non-teaching hospitals, with the exception of hemophilia (41 percent) and liver transplantation (10 percent). Fifty-six percent of cases occurred in hospitals with less than 500 beds.

Geographically, a majority of cases of rFVIIa use occured in the South (52 percent), with much smaller shares in the West (25 percent), Midwest (12 percent), and Northeast (11 percent). While the South is the most populous region in the U.S., the cases of rFVIIa use were disproportionate to its share of population (36 percent), total hospitalizations (38 percent), and hospital procedures (40 percent). In contrast, the Midwest and Northeast together (with 23 percent of cases) comprised comparable shares of population (40 percent), hospitalizations (41 percent), and hospital procedures (39 percent). These regional variations were present for most indications, including the FDA-approved indication of hemophilia, where 47 percent of cases occured in the South and only 7 percent in the West.68

Sensitivity analyses. We also conducted several sensitivity analyses of the coding scheme we used to define clinical indications for rFVIIa. In general, moving indications up or down in the hierarchy did not greatly change their reported frequency. While still modest, the greatest change occurred when trauma was moved to near the bottom of the hierarchy, reflecting the co-occurrence of other indications in patients with trauma (e.g., when a patient with liver disease experiences a traumatic injury). Nonetheless, we believe that it is reasonable to give trauma priority as a diagnosis in these instances, as it was likely trauma and not the associated diagnoses which instigated the use of rFVIIa.

### Overview of All Identified Comparative Studies of Off-Label rFVIIa Use

Our literature search identified 55 comparative studies on any off-label indication of rFVIIa use. Seventeen (31 percent) of these addressed clinical indications not assessed in Key Questions 2–4 of this review (Table 17).

Table 17 General characteristics of all comparative studies on off-label rFVIIa use for clinical indications not assessed in Key Questions 2–4

Article | Indication for rFVIIa use | Study Design | Study Setting Time Period | Sample Size and Dose, μg/kg | Mean Age (SD) [Range] | Outcomes Evaluated
| | | | | | Direct | Indirect
Other liver disease in cirrhotic patients
Jeffers 2002^142^ | Liver biopsy (cirrhotic patients) Prophylaxis | Non- comparative RCT^ | 3 centers USA Time period NR | All Rx: 71 5^*^: 5 5: 16 20: 14 80: 17 120: 19 *First 5 patients received a 5 ug/kg dose and were part of a non-randomized pilot study. | Rx: 5^*^: 46 (7) 5: 51 (10) 20: 49 (7) 80: 52 (9) 120: 50 (13) | Mortality Adverse events including TE events | Time to hemostasis
Bosch 2004^143^ | GI bleeding (cirrhotic patients) Treatment | RCT | 26 centers Europe 4/2001-4/2002 | Rx: 121 Ucare: 121 Dose: 100 ug/kg administered 8 times (800 ug/kg total) before first endoscopy and at 2, 4, 6, 12, 18, 24, and 30 hours later. | Rx: 54 (11) Ucare: 53 (12) | Mortality Adverse events including TE events | Transfusion requirements^†,†^ Efficacy of bleeding control
Shao 2006^144^ | Liver resection (cirrhotic patients) Prophylaxis | RCT | 7 centers China, Taiwan, Thailand 7/2001-12/2002 | All Rx: 155 50^*^: 71 100^*^: 74 Ucare: 76 *1^st^ Dose at time of skin cut, additional doses every 2 hours. Maximum of 4 doses. | Rx: 50: 53^U^ [22–76] 100: 54^U^ [23–72] Ucare: 49^U^ [30–75] | Mortality Adverse events including TE events | Transfusion requirements^†,†^ Blood loss
Bosch 2008^145^ | Variceal bleeding (cirrhotic patients) Treatment | RCT | 31 centers 12 countries in Europe and Asia 4/2004-8/2006 | All Rx: 170 300^*^: 85 600^*^: 85 Ucare: 86 *Total dose. Patients in the 600 ug/kg group given 200 + 4 x 100. Patients in the 300 ug/kg group given 200, 100 + 3 x placebo. | Rx: 300: 55 (12) 600: 55 (11) Ucare: 54 (10) | Mortality Adverse events including TE events | Efficacy of bleeding control
Shami 2003^146^ | Fulminant hepatic failure Prophylaxis | Retrospective comparative observational | 1 center Charlottesville, VA, USA 12/1999-NR | Rx: 7 Ucare: 8 Dose: 40 ug/kg, which could be repeated after placement of ICP transducer. | Rx: 34 [16–64] Ucare: 28 [7–45] | Mortality | Transfusion requirements^†,†^ Ability to place ICP transducer Efficacy of bleeding control
Obstetrics/gynecology
Ahonen 2007^147^ | Postpartum hemorrhage Treatment | Retrospective comparative observational | 1 center Helsinki, Finland Time period NR | Rx: 26 Ucare: 22 Mean dose: 100 ug/kg; SD: 14 ug/kg | Rx: 33 (4) Ucare: 35 (4) | Mortality Adverse events including TE events | Transfusion requirements^†,†^ Blood loss
Hossain 2007^148^ | Postpartum hemorrhage Treatment | Retrospective comparative observational | 1 center Karachi, Pakistan 3/2005-10/2006 | Rx: 18 Ucare: 16 Dose: 70 ug/kg, which was repeated in 3 patients. | Rx: 29^U^ [26–32]^I^ Ucare: 29^U^ [26–30]^I^ | Mortality TE events | Transfusion requirements^†,†^
McMorrow 2008^149^ | Postpartum hemorrhage Treatment | Retrospective comparative observational | 1 center Dublin, Ireland 2003–2006 | Rx: 6 Ucare: 6 Dose not reported | Rx: 34 (3) Ucare: 31 (5) | Mortality Adverse events including TE events | Transfusion requirements^†,†^
Hematology/oncology
Chuansumrit 2005^150^ | Dengue hemorrhagic fever (pediatric) Treatment | RCT | 5 centers Thailand, Philippines 7/2001-12/2002 | Rx: 16 Ucare: 9 Dose: 100 ug/kg with possible second dose 30 minutes later if bleeding not controlled | Rx: 9 (4) Ucare: 11 (3) | Mortality Adverse events including TE events | Transfusion requirements^†,†^ Efficacy of bleeding control
Pihusch 2005^151^ | Bleeding following hematopoietic stem cell transplantation Treatment | RCT | 21 centers Australia, Europe 4/2001-10/2003 | All Rx: 77 40^*^: 20 80^*^: 26 160^*^: 31 Ucare: 23 *study drug administered seven times over 36 hours. | Rx: 40: 36^U^ [20–58] 80: 38^U^ [20–61] 160: 37^U^ [16–57] Ucare: 39^U^ [18–64] | Mortality Adverse events including TE events | Transfusion requirements^†,†^ Efficacy of bleeding control
Gupta 2007^152^ | Alveolar hemorrhage in hematopeitic stem cell transplant recipients Treatment | Retrospective comparative observational | 1 center Houston, TX, USA 1/2002-12/2004 | Rx: 24 Ucare: 63 Dose not reported | Age not reported. | Mortality Adverse events including TE events | Requirement for positive pressure ventilation Hospital length of stay
Other surgery
Lodge 2005^153^ | Liver resection (non-cirrhotic patients) Prophylaxis | RCT | 13 centers France, Spain, Germany, UK 1/2001-1/2002 | All Rx: 122 20: 63 80: 59 Ucare: 63 | Rx: 20: 56 (13) 80: 56 (14) Ucare: 58 (12) | Mortality Adverse events including TE events | Transfusion requirements^†,†^ Blood loss Operating time
Raobaikady 2005^154^ | Reconstruction surgery for traumatic fracture of pelvis Prophylaxis | RCT | 1 center London, UK 8/2002-3/2004 | Rx: 24 Ucare: 24 Dose: 90 ug/kg given at first skin incision. Second dose given 2 hours later if transfusion of allogenic RBCs indicated. | Rx: 44^U^ [18–57] Ucare: 38^U^ [18–57] | Adverse events including TE events | Transfusion requirements^†,†^ Blood loss Operating time Hospital and ICU LOS
Johansson 2007^155^ | Burn patients undergoing excision and skin grafting Prophylaxis | RCT | 1 center Copenhagen, Denmark 6/2001-12/2003 | Rx: 9 Ucare: 9 Dose: Two 40 ug/kg doses given at start of surgery and 90 minutes later. | Rx: 54^U^ [22–85] Ucare: 38^U^ [19–81] | Mortality Adverse events including TE events | Transfusion requirements^†,†^ Operating time Hospital and ICU LOS
Sachs 2007^156^ | Spinal surgery Treatment | RCT | 13 Centers USA 7/2004-2/2006 | All Rx: 36 30^*^: 12 60^*^: 12 120^*^: 12 Ucare: 13 *3 doses given. First dose at bleeding trigger (10% loss of blood volume), second and third doses 2 and 4 hours later, respectively. | Rx: 30: 46 [18–62] 60: 46 [17–69] 120: 45 [18–63] Ucare: 50 [17–65] | Mortality Adverse events including TE events | Transfusion requirements^†,†^ Blood loss
Roitberg 2005^157^ | Neurosurgery Treatment | Retrospective comparative observational | 1 center Chicago, IL, USA 7/2001-11/2002 | Rx: 29 Ucare: 24 Dose not reported. | Rx: 60 Ucare: 57 | Mortality TE events Functional outcome (Glasgow outcome scale)
Kolban 2006^158^ | Scoliosis surgery (adolescents) Prophylaxis | Retrospective comparative observational | 1 center Szczecin, Poland 2000–2003 | Rx: 26 Ucare: 26 Mean dose: 23 ug/kg | Rx: 17 [10–22] Ucare: 16 [12–19] | Mortality Adverse events including TE events | Transfusion requirements^†,†^ Blood loss

U Median;

I Interquartile range;

† Examples of transfusion requirements were red blood cells and fresh frozen plasma

^ Dutton 2004^100^ has multiple control groups. The range of sample sizes is presented.

* Jeffers 2002 did not have a usual care (i.e. placebo) group, but randomized patients in a double-blind fashion to doses of 5, 20, 80, and 120 ug/kg rFVIIa.

Rx=treatment group(s); Ucare=usual care; NR=not reported; IQR=interquartile range; LOS=length of stay

Indications and populations for which rFVIIa has been studied. Comparative studies available for rFVIIa use in cardiac surgery (12), trauma (9), intracranial hemorrhage (8), liver transplantation (8), and prostatectomy(1) accounted for 69 percent (38/55) of all such studies. Additional indications included other liver disease (liver resection, liver biopsy, variceal bleeding, and all other liver-related indications), skin grafting, a variety of cranial and spinal neurosurgical procedures, orthopedic surgery, dengue hemorrhagic fever, and hematopoietic stem cell transplantation and other cancer treatment-related conditions.

While the leading off-label uses of rFVIIa (cardiac surgery, trauma, and intracranial hemorrhage) were each represented by a number of studies, beyond these indications there were different types of mismatches between patterns of in-hospital community practice use and the availability of comparative studies. There were prominent community uses that lacked studies, such as primary clotting disorders other than hemophilia, secondary clotting disorders, and gastrointestinal bleeding not related to liver disease. Other indications with no studies included aortic aneurysm, other vascular procedures, and neonatal use (beyond cardiac surgery). In contrast, there were indications that had been studied but where community use was limited. According to the Premier database, from 2005 to 2008 there were fewer than 30 annual cases of rFVIIa use in prostatectomy and liver transplantation. Use in pelvic fracture, skin grafting, and spine surgery also was limited. Finally, many studies examined only the mode of prophylactic rFVIIa use for clinical indications where treatment or end-stage use may also be frequent.

In general, study patients were younger and had lower clinical acuity than did patients in community practice (Table 16). This was particularly true for body trauma where the mean age in the community was 53 years compared to 32 years in the trauma RCTs. In addition, mortality rates in community practice (Table 16) generally were higher than those noted in the comparative studies. For example, in the intracranial hemorrhage RCTs, the reported 90 day mortality was 20 percent compared to 34 percent in-hospital mortality in the Premier database.

In summary, some study populations overlap with the major off-label indications for in-hospital rFVIIa use in community practice, while others represent indications with minimal use. Anticipated applicability of existing studies may be compromised by study of less acutely ill patients and a mismatch between indications studied and patterns of community use by indication and mode of use (i.e., prophylaxis versus treatment versus end -stage therapy).

Characteristics of comparative studies. The comparative studies of rFVIIa use compared this product to the usual care of hospitalized patients. There were 24 RCTs and 31 comparative observational studies (38 on Key Question 2–4 indications of which 22 (57.8 percent) had fair or better quality (Table 14)) available on rFVIIa use across a wide variety of clinical indications. Because the clinical circumstances of rFVIIa use differ so fundamentally between different indications, the suitability of pooling information across clinical indications is controversial.

Study sample sizes in existing comparative studies were generally small. Across all studies, the median and mean number of patients receiving rFVIIa were 24 and 58, respectively. For RCTs, the median and mean were 62.5 and 95, respectively. In addition, where multiple doses were studied it was typical to have fewer than 20 patients in each dosage arm. Evaluations of intracranial hemorrhage were the exception to the general rule of relatively low sample sizes, with the two largest RCTs together containing information on almost 900 patients treated with rFVIIa.

rFVIIa dosages varied enormously from 5 to 956 mcg/kg of patient weight for the studies examined in the effectiveness review s. The 5 mcg/kg dose was reported in several dose ranging studies. The large doses were used in studies where multiple doses were given over an extended time period and, given the 2.5 hour half-life of rFVIIa, the aggregate effect of these sequential doses may not have been greater than the effect of the single doses of 160–200 mcg/kg given in other studies.

The primary outcomes of most of the comparative studies were indirect outcomes that assessed surrogate markers or components of the health care process rather than patient -centered outcomes. Common outcomes included RBC transfusion requirements, blood loss, and duration of surgery or ICU stay. While these outcomes may be correlated with direct clinical outcomes, this correlation is incomplete and there are many instances where discrepancies are expected. Many studies included direct outcomes as secondary end-points. These included mortality, thromboembolic events, functional status, and other clinical events such as acute respiratory distress syndrome. Unfortunately, most studies were individually underpowered to evaluate these direct outcomes, although some studies of intracranial hemorrhage were an important exception.

It is also notable that most clinical trial research on rFVIIa was sponsored by Novo Nordisk, the product’s manufacturer. In many instances, clinical trials were directed and their data analyzed and reported with the involvement of the manufacturer.

Based on the characteristics of the published studies reviewed above, it is anticipated that the strength of evidence of these studies maybe compromised by small study size, inconsistent study quality, heterogeneity by dosage and indication, use of indirect outcomes, and potential conflicts of interest.

## Key Question 2. Intracranial hemorrhage and comparative effectiveness of rFVIIa

### Background

All of the RCTs evaluated in this section focus on intracerebral hemorrhage (ICH), rather than other forms of intracranial bleeding (e.g., subarachnoid or subdural hemorrhage). In the one comparative observational study, half of the patients had ICH while the other half had isolated subdural hematomas. Intracerebral hemorrhage is associated with high levels of mortality and functional disability. Over one third of patients die within one month, 50 percent have poor functional status at time of discharge, and 20 percent remain institutionalized at three months.159,160 Early hematoma growth occurs even in the absence of detectable systemic coagulopathy and is an important independent predictor of mortality and morbidity.33,161 There are no proven therapies for ICH.162 The purpose of this section is to describe the comparative studies of rFVIIa versus usual care for the treatment of intracranial hemorrhage, but the section necessarily focuses primarily on ICH because the majority of studies focused on this form of hemorrhage.

Usual care during the time frame of included studies. While there remains wide variation in practice patterns, usual care for ICH has evolved over the time span during which the studies included in this effectiveness review were conducted (February 2000 to February 2007). The most notable change in practice is the trend toward less tolerance of “permissive hypertension” because of the suggestion in recent studies, albeit far from conclusive, of increased hematoma expansion with higher blood pressures and potentially better outcomes with the control of blood pressure within six hours. 163–165 The largest and highest quality studies discussed below are those RCTs that were conducted most recently, between May 2005 and February 2007. The included trials did not specify hypertension management.

### General Characteristics of Studies of Intracranial Hemorrhage

In the area of ICH, we identified four published RCTs (two good quality,23,88 two fair quality86,87 (Table 14)) and one comparative observational study 89 (fair quality) that examined treatment use of rFVIIa in 968 intervention patients. The 944 patients who received rFVIIa in the RCTs were not on anticoagulation therapy and had experienced intracerebral hemorrhage (ICH), a subset of intracranial hemorrhage. All of the trials were performed by the same study group, were sponsored by the manufacturer of rFVIIa, and had at least one author or biostatistician who was an employee of the manufacturer. We identified an additional RCT on the Novo Nordisk site that appears to have been performed by a different research group and also sponsored by the manufacturer,166 but this study has not yet been published in any form, enrollment is small (45 patients in treatment and control groups, respectively), and the online posting gives only summary details. In the comparative observational study by Ilyas 2008,^89^ half of the patients had experienced ICH and the other half had experienced subdural hematomas as their manifestation of intracranial hemorrhage.

Place of studies within analytic framework. All of the included studies of intracranial hemorrhage evaluated rFVIIa for treatment use (versus prophylaxis or end-stage use, which are other potential uses, as outlined in our Analytic Framework (Figure 1)). The RCTs had well-documented approaches to data collection and analysis of direct outcomes such as mortality, thromboembolic events, and functional outcome, although only one of them was powered to analyze direct outcomes as its primary outcome, and it used a combined endpoint of “severe disability or death.”88 The Ilyas observational study examined time to correction of INR as its primary endpoint.

Qualitative considerations of heterogeneity. Intracranial hemorrhage can occur inside the hemispheres of the brain (i.e., intracerebral hemorrhage, or ICH) or around the hemispheres (e.g., sudural or subarachnoid bleeding). Because the underlying causes and associated risks of these types of bleeding can vary, we considered results for them separately. Second, baseline coagulopathy is another source of potiential heterogeneity, because patients who are coagulopathic—generally from oral anticoagulation therapy with warfarin —may differ in important ways from those who are not coagulopathic. Again, we considered these patient groups separately in our discussion. Third, because there were indications in the literature regarding a possible dose response relationship between rFVIIa and certain outcomes (e.g., thromboembolic events) and multiple doses of rFVI were analyzed in each RCT, we chose to analyze the data according to low, medium, and high dose rFVIIa groups, as described in our methods and defined as less than or equal to 40 μg/kg, greater than 40 but less 120 μg/kg, and at least 120 μg/kg, respectively. Finally, three of the RCTs defined “poor functional outcome” as a modified Rankin scale score of 4–6, whereas the fourth RCT defined it as a a score of 5–6 but also included a graphical representation of the scores which allowed us to perform our own calculation of the proportion of patients with scores of 4–6, such that the data could be combined with the other RCTs.

Comparison to studies on other indications. The RCTs on ICH had the longest and most comprehensive follow-up of all of the indications. The largest of them also enrolled more patients than studies in any other indication. On average, the patients tended to be older than those in most other indications, but were similar to those in adult cardiac surgery and prostatectomy. The dose range of rFVIIa was from the low-to-middle range of doses used across indications.

### Patient Characteristics and Study Design

RCTs. Table 18 summarizes important characteristics of each of the trials, all of which had similar patient populations and methodologies. The two large RCTs randomized a total of 399 and 841 patients respectively,23,88 whereas the smaller trials randomized 47 and 40 patients, respectively.86,87 In all of the trials, important inclusion criteria were that patients were required to have received a baseline CT scan within 3 hours of symptoms onset and study drug within 4 hours. Similarly, important shared exclusion criteria were that a patient was known to be taking oral anticoagulants, was in a deep coma, or was anticipated to need surgical evacuation within 24 hours. Overall, the groups randomized to rFVIIa versus usual care were similar on key baseline characteristics such as age, location of hemorrhage, Glasgow Coma Scale (GCS) score (a scale of neurological function), blood pressure, and time to treatment with rFVIIa or placebo. A possible exception to the groups being well-matched occurred in the largest and most recent RCT, which identified a higher rate of baseline intraventricular hemorrhage in the group that received 80 mcg/kg of rFVIIa compared to the usual care group.88 The mean age of patients in the aggregate treatment and usual care groups in every trial was between 61 and 68 years, with standard deviations in the range of 12–15. In general, the RCTs used appropriate methods of blinding, in particular with the blinding of the two radiologists who independently measured the hematoma size and growth on all of the head computed tomography (CT) scans. In addition, the RCTs had appropriately long follow-up periods of 90 days, had very low rates of loss to follow-up, applied an intention-to-treat approach, and used appropriate statistical analyses.

Table 18 General characteristics of comparative studies on off-label rFVIIa use for intracranial hemorrhage

Article | Study Design | Study Setting/Time Period | Sample Size and Dose, μg/kg | Population Characteristics | | Outcomes Evaluated
| | | | Mean Age(SD) [Range] | Inclusion/Exclusion Criteria | Direct | Indirect
Mayer 2005a23 | RCT Treatment | 73 centers Australia, Europe, Asia, North America 8/2002–3/2004 | All Rx: 303 40: 108 80: 92 160: 103 Ucare: 96 | Rx: 40: 67 (12) 80: 65 (12) 160: 64 (13) Ucare: 68 (12) | Inclusion: -spontaneous ICH -treatment within 4 hrs of symptoms onset -over 18 years old Exclusion: -deep coma (GCS 3–5) -surgical hematoma evacuation planned within 24h -secondary ICH (e.g. related to trauma) -known oral anticoagulant use, history of coagulopathy, or thrombocytopenia -any history of thrombotic disease^*^ -previous disability (mRS>2) | Mortality Adverse events including TE events Poor functional outcome (mRS 4–6) | Change in hematoma volume
Mayer 2005b86 | RCT Treatment | 14 centers Australia, Europe, Asia 8/2001–10/2002 | All Rx: 36 10: 6 20: 6 40: 6 80: 6 120: 6 160: 6 Ucare: 11 | Rx: 10: 51 (9) 20: 68 (22) 40: 68 (16) 80: 58 (11) 120: 64 (14) 160: 53 (12) Ucare: 66 (14) | Inclusion: -spontaneous ICH -treatment within 4 hrs of symptoms onset -over 18 years old Exclusion: -deep coma (GCS 3–5) -surgical hematoma evacuation planned within 24h -secondary ICH (e.g. related to trauma) -known oral anticoagulant use, history of coagulopathy, or thrombocytopenia -any history of thrombotic disease -previous disability (mRS>2) | Mortality Adverse events including TE events Poor functional outcome (mRS 4–6)
Mayer 2006^87^ | RCT Treatment | 17 centers USA 11/2001–3/2003 | All Rx: 32 5: 8 20: 8 40: 8 80: 8 Ucare: 8 | Rx: 5: 72 (10) 20: 60 (15) 40: 64 (13) 80: 62 (12) Ucare: 67 (13) | Inclusion: -spontaneous ICH -treatment within 4 hrs of symptoms onset -over 18 years old Exclusion: -deep coma (GCS 3–5) -surgical hematoma evacuation planned within 24h -secondary ICH (e.g. related to trauma) -known oral anticoagulant use, history of coagulopathy, or thrombocytopenia -any history of thrombotic disease -previous disability (mRS>2) | Mortality Adverse events including TE events Poor functional outcome (mRS 4–6) | Change in hematoma volume
Mayer 2008^88^ | RCT Treatment | 122 centers Australia, Europe, Asia, North America 5/2005–2/2007 | All Rx: 573 20: 276 80: 297 Ucare: 268 | Rx: 20: 65 (14) 80: 65 (13) Ucare: 65 (14) | Inclusion: -spontaneous ICH -treatment within 4 hrs of symptoms onset -over 18 years old Exclusion: -deep coma (GCS 3–5) -surgical hematoma evacuation planned within 24h -secondary ICH (e.g. related to trauma) -known oral anticoagulant use, history of coagulopathy, or thrombocytopenia -known recent thrombotic disease (within 30 days of enrollment) -previous disability (mRS>2) | Mortality Adverse events including TE events Poor functional outcome (mRS 5–6, but with extrapolation possible to mRS 4–6) | Change in hematoma volume
Ilyas 2008^89^ | Retrospective comparative Treatment | 1 University hospital USA 2/2000-NR | Rx: 24 Range 10–100 Ucare:30 | Rx: 76.5 (11) Ucare: 76.4 (12.4) | Inclusion: -new or evolving intracranial hemorrhage (ICH or subdural hematoma) -use of warfarin -INR>1.4 Exclusion: NR | Mortality Adverse events including TE events | Time to correction of INR
Pickard 2000^90,†^ | Prospective comparative Treatment | Multicenter NR NR | All Rx: 5 80: 2 80+3.5/h CI: 2 80+7.0/h CI: 1 UCare: 5 | Rx: NR UCare: NR | Inclusion: -subarachnoid hemorrhage (grade I, II, or III on World Federation of Surgeons scale) confirmed on head CT or lumbar puncture Exclusion: NR | Adverse events including TE events | PET scan markers of cerebral blood flow and oxygen extraction
Brody 2005^91,†^ | Retrospective comparative Treatment | 1 University hospital USA 3/2002–1/2003 | Rx: 12 Mean 4.8 mg SD 2.1 mg UCare 15 | Rx: 71 (13) UCare: 77 (7) | Inclusion: -spontaneous warfarin-associated ICH -INR>1.3 Exclusion: NR | Mortality Adverse events including TE events Functional outcome (GCS) | ICU and hospital LOS
Hallevi 2008^92,†^ | Retrospective comparative Treatment | 1 University hospital USA NR | All Rx: 46 40 (on warfarin): NR 80 (not on warfarin): NR UCare: 148 | Rx: 60 [38–87] UCare: 58 [40–80] | Inclusion: -spontaneous ICH (could include those on warfarin) Exclusion: -GCS<5 -Recent thromboembolic event | Mortality Adverse events including TE events Functional outcome (mRS) | Change in hematoma volume

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report;

* Mayer 2005a23 excluded patients with symptomatic thrombotic or vaso-occlusive disease within 30 days of symptoms onset. This was amended midway through the trial to exclude patients with any history of thrombotic of vaso-occlusive disease;

Rx=treatment group(s); Ucare=usual care; GCS=Glasgow Coma Scale; mRS=modified Rankin Scale; CI=continuous infusion; ICU=intensive care unit; LOS=length of stay

Comparative observational study. Unlike the above RCTs, the one comparative observational study by Ilyas89 included patients on oral anticoagulation therapy with warfarin (INR>1.4) and with subdural hematomas or ICH (50 percent apiece). It retrospectively compared 24 patients treated with rFVIIa to 30 usual care patients.

### Intervention Characteristics

RCTs. The rFVIIa dose was administered similarly in all of the studies: packaged in identical vials to placebo and administered as a single dose within one hour of baseline head CT scan and four hours of symptoms onset. The doses varied widely, however. The smaller dose -finding studies had the widest variation, with doses of 10, 20, 40, 80, 120, and 160 μg/kg,86 and 5, 20, 40, and 80 μg/kg,87 respectively, with equal numbers of patients per dose tier in a given study. The larger studies had less variation in dose range, with 20 and 80 μg/kg,23 and 40, 80, and 160 μg/kg,88 respectively, and also had similar numbers of patients within each dose tier.

Comparative observational study. There was a wide dose range of 10–100 μg/kg among treated patients in the Ilyas study.89

### Outcomes

As explained in our methods, for the intracranial hemorrhage indication there were special statistical considerations, such that we made several a priori decisions regarding statistical analyses. Because there were indications in the literature regarding a possible dose response relationship between rFVIIa and certain outcomes (e.g., thromboembolic events and hematoma volume) and multiple doses of rFVI were analyzed in each RCT, we chose to analyze the data according to low, medium, and high dose rFVIIa groups, defined as less than or equal to 40 μg/kg, greater than 40 but less 120 μg/kg, and at least 120 μg/kg, respectively. However, in all of the RCTs, the different levels of treatment dosage were compared to a common control. In addition, some studies did not contain all levels of the treatment dosage. Because of these complexities, we applied meta-analytic methods developed by Olkin et al82 to analyze this kind of data when generating the summary effect sizes. Second, because there were suggestions in the literature of a possible association between rFVIIa and arterial thromboembolic events, but not venous events, and both types of data were available to us from the ICH RCTs, we chose to analyze arterial and venous thromboembolic events separately for this indication. Third, while the summary effect sizes for all analyses (included in both the text and figures) are indeed accurate, their graphical representation using forest plots is complicated by their use of a common control for the different treatments dosages, so should be considered an aide to interpretation rather than a strict representation of the underlying metrics employed. Fourth, among the studies included in the risk difference meta-analyses, assessments of the significance and magnitude of heterogeneity by the Q and I^2^ statistics did not identify significant heterogeneity for any outcome. Finally, meta-analytic results using the arcsine metric were consistent in all cases with those described below for the risk difference (Appendix C, Appendix Figures 1–9).

Direct (patient-centered) outcomes. There were no dose-dependent trends in the outcomes reported. Because the RCTs had similar patient populations and measured comparable outcomes, we were able to perform meta-analyses of their data for all major outcomes. The direct (patient-centered) outcomes are presented in Tables 19 and 20 and in Figures 5 –18. We also plotted mean differences in mortality and thromboembolic event rates for each comparative study and according to each rFVIIa indication using circle charts, with the area of each circle approximating the total sample size of its respective study (Figures 5 and 6).

Figure 5 Mean differences in mortality rates, by study and rFVIIa indication (rFVIIa minus usual care)

Figure 5 illustrates the meta-analytic evaluation of differences in mortality rates in the context of the comparable findings for several clinical indications and by comparative study. In the figure, several circles are plotted where each circle represents a study; larger circles correspond to larger studies; shaded circles represent studies on treatment use of rFVIIa, and white circles represent studies on prophylactic use of rFVIIa. Trauma and Intracranial hemorrhage have five shaded circles. Traumatic brain injury has two shaded circles. Liver Transplantation has four circles that are not shaded. Adult Cardiac Surgery has five circles - four are shaded; one is not. The risk difference summary statistics are reported below Figure D. In sum, there was no effect of rFVIIa on mortality.

Figure 6 Mean differences in rates of thromboembolic events, by study and rFVIIa indication (rFVIIa minus usual care)

ICH=intracranial hemorrhage here—although in rest of report “ICH” indicates a subset of intracranial hemorrhage, namely intracerebral hemorrhage; Trauma=body trauma; TBI=brain trauma (traumatic brain injury); LvrTx=liver transplantation; AdCS=adult cardiac surgery The figures show mean differences in mortality and thromboembolic event rates, respectively, for each comparative study and according to each rFVIIa indication. The area of each circle approximates the total sample size of each respective study; shaded circles represent studies on treatment use of rFVIIa and clear circles represent studies on prophylactic use of rFVIIa.

Figure 6 illustrated the meta-analytic evaluation of thromboembolic event risk differences rates in the context of the comparable findings for several clinical indications and by comparative study. In the figure, several circles are plotted where each circle represents a study; larger circles correspond to larger studies; shaded circles represent studies on treatment use of rFVIIa, and white circles represent studies on prophylactic use of rFVIIa. The risk difference summary statistics are reported below Figure D. In sum, there was an increased rate of arterial thromboembolic events with rFVIIa use vs. usual care for the medium- and high-dose groups.

Figure 7 Mortality in ICH (low rFVIIa dose)

Figure 7 depicts a random effects model of mortality in ICH with low rFVIIa dose. The summary statistics are as follows: Risk difference summary effect size -0.031 (95%CI: -0.086 to 0.024); P value for Q statistic: 0.248; I-Squared=22.73

Figure 8 Mortality in ICH (medium rFVIIa dose)

Figure 8 depicts a random effects model of mortality in ICH with medium rFVIIa dose. The summary statistics are as follows: Risk difference summary effect size -0.02 (95%CI: -0.076 to 0.036); P value for Q statistic: 0.248; I-Squared=22.73

Figure 9 Mortality in ICH (high rFVIIa dose)

Figure 9 depicts a random effects model of mortality in ICH with high rFVIIa dose. The summary statistics are as follows: Risk difference summary effect size -0.027 (95%CI: -0.121 to 0.068) ; P value for Q statistic: 0.248; I-Squared=22.73

Figure 10 Poor modified Rankin score in ICH (low rFVIIa dose)

Figure 10 depicts a random effects model of poor modified Rankin score in ICH with low rFVIIa dose. The summary statistics are as follows: Risk difference summary effect size -0.024 (95%CI: -0.092 to 0.045); P value for Q statistic: 0.088; I-Squared=43.53

Figure 11 Poor modified Rankin score in ICH (medium rFVIIa dose)

Figure 11 depicts a random effects model of poor modified Rankin score in ICH with medium rFVIIa dose. The summary statistics are as follows: Risk difference summary effect size -0.029 (95%CI: -0.099 to 0.041); P value for Q statistic: 0.088; I-Squared=43.53

Figure 12 Poor modified Rankin score in ICH (high rFVIIa dose)

Figure 12 depicts a random effects model of poor modified Rankin score in ICH with high rFVIIa dose. The summary statistics are as follows: Risk difference summary effect size -0.04 (95%CI: -0.154 to 0.075) P-value for Q statistic: 0.088; I-Squared=43.53

Figure 13 Arterial TE events in ICH (low rFVIIa dose)

Figure 13 depicts a random effects model of arterial TE events in ICH with low rFVIIa dose. The summary statistics are as follows: Risk difference summary effect size 0.025 (95%CI: -0.004 to 0.053) P-value for Q statistic: 0.277; I-Squared=19.29

Figure 14 Arterial TE events in ICH (medium rFVIIa dose)

Figure 14 depicts a random effects model of arterial TE events with medium rFVIIa dose. The summary statistics are as follows: Risk difference summary effect size 0.035 (95%CI: 0.008 to 0.062) P-value for Q statistic: 0.277; I-Squared=19.29

Figure 15 Arterial TE events in ICH (high rFVIIa dose)

Figure 15 depicts a random effects model of arterial TE events with high rFVIIa dose. The summary statistics are as follows: Risk difference summary effect size 0.063 (95%CI: 0.011 to 0.114) P-value for Q statistic: 0.277; I-Squared=19.29

Figure 16 Relative change in hematoma volume for ICH (low rFVIIa dose)

Figure 16 depicts a random effects model of relative change in hematoma volume for ICH with low rFVIIa dose. The summary statistics are as follows: Standardized mean difference -0.157 (95%CI: -0.302 to -0.012) P-value for Q statistic: 0.653; I-Squared=0

Figure 17 Relative change in hematoma volume for ICH (medium rFVIIa dose)

Figure 17 depicts a random effects model of relative change in hematoma volume for ICH with medium rFVIIa dose. The summary statistics are as follows: Standardized mean difference -0.293 (95%CI: -0.439 to -0.148) P-value for Q statistic: 0.653; I-Squared=0

Figure 18 Relative change in hematoma volume for ICH (high rFVIIa dose)

Figure 18 depicts a random effects model of relative change in hematoma volume for ICH with high rFVIIa dose. The summary statistics are as follows: Standardized mean difference -0.304 (95%CI: -0.549 to -0.06) P-value for Q statistic: 0.653; I-Squared=0

Table 19 Mortality and poor outcome on modified Rankin Scale score in comparative studies of rFVIIa use in intracranial hemorrhage

Article | Study Design and rFVIIa use | Mean rFVIIa dose (ug/kg) (SD) [Range] | Sample size^ | | Mean age (SD) [Range] | | Mortality rate | | | Poor functional outcome on mRS^*^ rate
| | | rFVIIa | Usual care | rFVIIa | Usual care | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig
Mayer 2005a23 | RCT Treatment | 40 80 160 | 108 92 103 | 96 | 67 (12) 65 (12) 64 (13) | 68 (12) | 0.176 0.185 0.194 | 0.292 | p=.05 p=.10 p=.11 | 0.546 0.495 0.544 | 0.688 | p=.02 p=.008 p=.02
Mayer 2005a23 | All Patients | | | | - | - | 0.185 | 0.292 | p=.02 | 0.530 | 0.688 | p=.004
Mayer 2005b86 | RCT Treatment | 10 20 40 80 120 160 | 6 6 6 6 6 6 | 11 | 51 (9) 68 (22) 68 (16) 58 (11) 64 (14) 53 (12) | 66 (14) | 0 0 0.167 0 0.167 0.167 | 0.182 | NR | 0 0.333 0.667 0.5 0.5 0.667 | 0.455 | NR
Mayer 2005b86 | All Patients | | | | - | - | 0.083 | 0.182 | NR | 0.444 | 0.455 | NR
Mayer 2006^87^ | RCT Treatment | 5 20 40 80 | 8 8 8 8 | 8 | 72 (10) 60 (15) 64 (13) 62 (12) | 67 (13) | 0.25 0.25 0.375 0 | 0.125 | NR | 0.625 0.375 0.625 0.25 | 0.500 | NR
Mayer 2006^87^ | All Patients | | | | - | - | 0.219 | 0.125 | NR | 0.469 | 0.500 | NR
Mayer 2008^88^ | RCT Treatment | 20 80 | 276 297 | 268 | 65 (14) 65 (13) | 65 (14) | 0.181 0.209 | 0.190 | p=.38 p=.75 | 0.492 0.505 | 0.466 | 1.0 [0.6–1.6]^#^ 1.4 [0.9–2.2]^#^
Mayer 2008^88^ | All Patients | | | | - | - | 0.195 | 0.190 | NR | 0.499 | 0.466 | NR
RCTs Unweighted sum | All RCTs | 5–40 80 120–160 | 426 403 115 | 383 | - | - | 0.181 0.196 0.191 | 0.214 | | 0.502 0.497 0.548 | 0.522
RCTs Unweighted sum | All Patients | | | | - | - | 0.189 | 0.214 | | 0.506 | 0.522
Ilyas89 | Retrospective comparative Treatment | [10–100] | 24 | 30 | 76.5 (11) | 76.4 (12.4) | 0.21 | 0.27 | p=.86 | NR | NR | NR
Pickard 2000^90,†^ | Prospective comparative Treatment | 80; 80+3.5/h CI; 80+7.0/h CI | 5 | 5 | NR | NR | NR | NR | NR | NR | NR | NR
Brody 2005^91,†^ | Retrospective comparative Treatment | 4.8& (2.1) | 12 | 15 | 71 (13) | 77 (7) | 0.42 | 0.13 | NR | $ | $ | NR
Hallevi 2008^92,†^ | Retrospective comparative Treatment | 40;80 | 46 | 148 | 60 [38–87] | 58 [40–80] | 0.13 | 0.14 | NR | 0.57 | 0.54 | NR

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

^ This is the largest sample size reported in each study, which is the correct sample size for mortality. Sample size for poor functional outcome on the modified Rankin Scale (mRS) was smaller in Mayer NEJM 2005^23^ and Mayer NEJM 2008:^88^ 108, 91, 103, and 96 in the 40, 80, 160, and usual care groups, respectively in Mayer NEJM 2005^23^, and 264, 293, and 262 in the 20, 80, and usual care groups, respectively in Mayer NEJM 2008^88^ Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies, wherever possible.

* Poor outcome defined as modified Rankin Scale (mRS) score of 4–6. Data for mRS scores of 4–6 in Mayer NEJM 2008^88^ were derived graphically from figure 3 in the paper. The proportion of patients with mRS scores of 5–6 was reported as 0.261, 0.287, 0.237 for the 20 ug/kg, 80 ug/kg, and usual care groups, respectively. The odds ratio reported for Mayer NEJM 2008^88^ is based upon the proportion of patients with mRS scores of 5–6.

# Odds ratio for poor functional outcomes and 95 percent confidence interval (CI), based upon the proportion of patients with mRS scores of 5–6.

& Mean dose in mg rather than ug/kg of body weight.

$ Brody 2005^91^ reports median (range) GCS score at discharge by group (15=normal, 0=dead): rFVIIa 13.5 (13–15), usual care 15 (13–15).

mRS=modified Rankin Scale; NR=not reported; CI=continuous infusion

Table 20 Thromboembolic events (arterial and venous) in comparative studies of rFVIIa use in intracranial hemorrhage

Article | Study Design and rFVIIa use | Mean rFVIIa dose (ug/kg) (SD) | Sample size^^ | | Mean age (SD) [Range] | | Total Thromboembolic Event Rate^**^ | | | Arterial Thromboembolic Event Rate^**^ | | | Venous Thromboembolic Event Rate^**^
| | | rFVIIa | Usual care | rFVIIa | Usual care | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig
Mayer 2005a23 | RCT Treatment | 40 80 160 | 108 92 103 | 96 | 67 (12) 65 (12) 64 (13) | 68 (12) | 0.065 0.043 0.097 | 0.021 | NR | 0.056 0.022 0.078 | 0 | NR | 0.009 0.022 0.019 | 0.021 | NR
Mayer 2005a23 | All Patients | | | | | | 0.069 | 0.021 | p=.12 | 0.053 | 0 | p=.0 1 | 0.017 | 0.021 | NR
Mayer 2005b86 | RCT Treatment | 10 20 40 80 120 160 | 6 6 6 6 6 6 | 11 | 51 (9) 68 (22) 68 (16) 58 (11) 64 (14) 53 (12) | 66 (14) | 0 0.333 0.333 0 0 0 | 0.091 | NR | 0 0.167 0.333 0 0 0 | 0 | NR | 0 0.167 0 0 0 0 | 0.091 | NR
Mayer 2005b86 | All Patients | | | | | | 0.111 | 0.091 | NR | 0.083 | 0 | NR | 0.028 | 0.091 | NR
Mayer 2006^87^ | RCT Treatment | 5 20 40 80 | 8 8 8 8 | 8 | 72 (10) 60 (15) 64 (13) 62 (12) | 67 (13) | 0 0.25 0.125 0 | 0.125 | NR | 0 0 0 0 | 0.125 | NR | 0 0.25 0.125 0 | 0 | NR
Mayer 2006^87^ | All Patients | | | | | | 0.094 | 0.125 | NR | 0 | 0.125 | NR | 0.094 | 0 | NR
Mayer 2008^^88 | RCT Treatment | 20 80 | 265 293 | 263 | 65 (14) 65 (13) | 65(14) | 0.098 0.126 | 0.087 | NR | 0.057 0.092 | 0.046 | NR p=.0 4 | 0.042 0.034 | 0.042 | NR NR
Mayer 2008^^88 | All Patients | | | | | | 0.113 | 0.087 | NR | 0.075 | 0.046 | NR | 0.038 | 0.042 | NR
Unweighted Sum | All RCTs | 5–40 80 120–160 | 415 399 115 | 378 | | | 0.096 0.103 0.087 | 0.071 | | 0.058 0.072 0.070 | 0.034 | | 0.039 0.030 0.017 | 0.037
Unweighted Sum | All Patients | | | | | | 0.098 | 0.071 | | 0.066 | 0.034 | | 0.032 | 0.037
Ilyas 2008^89^ | Retrospective comparative Treatment | [10–100] | 24 | 30 | 76.5 (11) | 76.4 (12.4) | 0.04 | 0 | NR | 0.04 | 0 | NR | 0 | 0 | NR
Pickard 2000^90,†^ | Prospective comparative Treatment | 80; 80+3.5CI; 7.0 CI | 5 | 5 | NR | NR | 0.2 | 0 | NR | 0.2 | 0 | NR | 0 | 0 | NR
Brody 2005^91,†^ | Retrospective comparative Treatment | 4.8& (2.1) | 12 | 15 | 71 (13) | 77 (7) | 0.25 | 0 | NR | 0.08 | 0 | NR | 0.17 | 0 | NR
Hallevi 2008^92,†^ | Retrospective comparative Treatment | 40;80 | 46 | 148 | 60 [38–87] | 58 [40– 80] | 0.15 | NR | NR | 0.09 | NR | NR | 0.07 | NR | NR

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report. Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies, wherever possible.

^^ Sample size for thromboembolic events in Mayer NEJM 2008^88^ is smaller than reported for mortality and poor mRS because thromboembolic event rates were calculated based upon the “safety population” (i.e. patients exposed to a study agent) rather than the patients subjected to randomization.

** Thromboembolic event rates were calculated by dividing the number of thromboembolic events by the sample size, not the number of patients who experienced thromboembolic events. Therefore, the rates reported here may differ slightly from the rates reported in each study. The tests of statistical significance presented are those reported by the individual studies and are not based upon the thromboembolic event rates reported in this table.

& Mean dose in mg rather than ug/kg of body weight.

CI=continuous infusion; NR=not reported; NS=not significant

[underlined: Mortality.] Meta-analytic evaluation of mortality rate indicated no difference between the aggregate rFVIIa patients and the usual care patients (Figures 7–9)( risk difference: low dose −0.031 (95 percent CI −0.086 to 0.024), medium dose −0.020 (95 percent CI −0.076 to 0.036), high dose −0.027 (95 percent CI −0.121 to 0.068); P value of the Q statistic for all risk differences 0.248). The mean mortality rate differences between rFVIIa and usual care groups by study are shown and placed in the context of other indications in Figure 5. The Ilyas observational study of patients on warfarin also found no difference in mortality between groups (Table 19).

[underlined: Poor modified Rankin Scale.] Poor modified Rankin Scale (mRS) score is the most widely accepted, validated measure of functional outcome in ICH. Note that other functional outcome measurements were assessed in most of the ICH studies and had similar outcomes to those reported for the mRS. Meta-analytic evaluation of poor mRS score indicate d no difference in outcomes between the aggregate rFVIIa patients and the usual care patients (Figures 10–12)( risk difference: low dose −0.024 (95 percent CI −0.093 to 0.045), medium dose −0.029 (95 percent CI −0.099 to 0.041), high dose −0.040 (95 percent CI −0.154 to 0.075); P value of the Q statistic for all risk differences 0.088).

[underlined: Thromboembolic events.] Meta-analytic evaluation of arterial thromboembolic events identified significantly higher rates with rFVIIa use compared to usual care for the medium and high dose groups and a similar, but non-significant, finding for the low dose group (Figures 13–15) (risk difference: low dose 0.025 (95 percent CI −0.004 to 0.053), medium dose 0.035 (95 percent CI 0.008 to 0.062), high dose 0.063 (95 percent CI 0.011 to 0.063); P value of the Q statistic for all risk differences 0.277). These results suggest that there is an increase in arterial thromboembolic events with rFVIIa use versus usual care. There were no differences between groups in venous thromboembolic events (risk difference: low dose 0.010 (95 percent CI −0.018 to 0.038), medium dose −0.004 (95 percent CI −0.030 to 0.022), high dose −0.012 (95 percent CI −0.049 to 0.026); P value of the Q statistic for all risk differences 0.935). The Ilyas observational study of patients on warfarin noted only one thromboembolic event in any group, a myocardial infarction in a rFVIIa patient (Table 20). Figure 6 displays for each study, and also in the context of studies of the other indications, the mean rate differences for all thromboembolic events (venous and arterial) between the rFVIIa and usual care groups.

Indirect (surrogate) outcomes. Relative hematoma expansion. Meta-analytic evaluation of relative hematoma expansion demonstrated significant reductions in the rFVIIa group compared to the usual care group at all dosing levels (standardized mean difference: low dose −0.146 (95 percent CI −0.291 to −0.001), medium dose −0.240 (95 percent CI −0.385 to −0.095), high dose −0.334 (95 percent CI −0.579 to −0.090); P value of the Q statistic for all standardized mean differences 0.840) (Figures 16–18). While the large Mayer 2005a21 study reported a significant dose-response effect of reduced hematoma growth with higher doses of rFVIIa, statistical tests for differences between dosing levels in our meta-analyses found no significant dose effect. The Ilyas study did not report on this outcome(Table 21).

Table 21 Indirect outcomes in comparative studies of rFVIIa use in intracranial hemorrhage

Article | Study Design/rFVIIa use | rFVIIa dose (ug/kg) (SD) [Range] | Sample size | | Mean age (SD) [Range] | | Relative hematoma expansion, % [95 percent CI], (SD) | | | Absolute hematoma expansion, mL [95 percent CI], (SD)
| | | rFVIIa | UC | rFVIIa | UC | rFVIIa | UC | Sig | rFVIIa | UC | Sig
Mayer 2005a23 | RCT Treatment | 40 80 160 | 108 92 103 | 96 | 67 (12) 65 (12) 64 (13) | 68 (12) | 16 [4–28]^*^ 14 [2–27]^*^ 11 [0–23]^*^ | 29 [16–44]^*^ | p=.07 p=.05 p=.02^ All Pts: p=.01^ | 5.4 [1.7–9.0]^*^ 4.2 [0.3–8.0]^*^ 2.9 [−0.8–6.6]^*^ | 8.7 [4.9–12.4]^*^ | p=.13 p=.14 p=.008^ All Pts: p=.01^
Mayer 2005b86 | RCT Treatment | 10 20 40 80 120 160 | 6 6 6 6 6 6 | 11 | 51 (9) 68 (22) 68 (16) 58 (11) 64 (14) 53 (12) | 66 (14) | “same” | “same” | Not significant | NR | NR | NR
Mayer 2006^87^ | RCT Treatment | 5 20 40 80 | 8 8 8 8 | 8 | 72 (10) 60 (15) 64 (13) 62 (12) | 67 (13) | 64 (106) 79 (172) 37 (51) 4 (9) | 11 (18) | Not significant | 13 (19) 10 (21) 1 (2) 1 (2) | 2 (4) | Not significant
Mayer 2008^88^ | RCT Treatment | 20 80 | 276 297 | 268 | 65 (14) 65 (13) | 65 (14) | 18 [13–24] 11 [6–17] | 26 [20–32] | p=.09 p=<.001 | 4.9 [2.9–7.0] 3.7 [1.7–5.7] | 7.5 [5.4–9.6] | p=.08 p=.009
Ilyas 2008^89^ | Retrospective comparative Treatment | [10–100] | 24 | 30 | 76.5 (11) | 76.4 (12.4) | NR | NR | NR | NR | NR | NR
Pickard 2000^90,†^ | Prospective comparative Treatment | 80; 80+3.5/h CI; 80+7.0/h CI | 5 | 5 | NR | NR | NR | NR | NR | NR | NR | NR
Brody 2005^91,†^ | Retrospective comparative Treatment | 4.8& (2.1) | 12 | 15 | 71 (13) | 77 (7) | NR | NR | NR | NR | NR | NR
Hallevi 2008^92,†^ | Retrospective comparative Treatment | 40;80 | 46 | 148 | 60 [38–87] | 58 [40– 80] | 11.6 (14.6) | NR | NR | 1.09 (1.37) | NR | NR

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report;

.Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies.

* In Mayer 2005a,23 98.3 percent confidence interval is used;

^ The comparison was statistically significant according to the prespecified Bonferroni-corrected threshold of p=0.0167 in Mayer 2005a23;

& Mean dose in mg rather than ug/kg of body weight;

UC=usual care; CI=continuous infusion; NR=not reported

Consideration of poor quality comparative observational studies. In the poor quality comparative observational studies by Pickard,90 Brody,91 and Hallevi,92 the findings on mortality, poor functional outcome, and thromboembolic events are within the range of those described above (Tables 19 and 20).Other outcomes were not reported.

### Other Considerations

#### Timing of rFVIIa and Changes in ICH Volume

[underlined: Background]. Until recently, increases in ICH volume were thought to be completed within minutes of onset, but recent studies have shown continued growth of the hemorrhage up to several hours after symptoms onset.167 Additionally, this late growth of the ICH has been associated with neurological deterioration and poor clinical outcome.33,167 A pooled meta-analysis of individual patient data from the earlier RCTs23,86,87 and a study by Brott et al. 167 showed that for each 10 percent increase in ICH between the baseline CT scan (performed within 3 hours of symptoms onset) and follow up CT performed 24 hours after the baseline, the hazard rate of dying increased by five percent. Similarly, the hazard ratio of increasing the modified Rankin Scale by one point (toward worse functional outcomes), was 16 percent for each 10 percent increase in ICH growth.33 In this section we explore the association between timing of rFVIIa and hemorrhage growth.

[underlined: Results.] Table 22 shows the published data from the largest of the earlier 2 ICH RCTs, Mayer 2005a,23 but compares those patients treated within three hours of symptoms onset to those treated after three hours from symptoms onset, but still within the four-hour time window established by the study as an inclusion criterion. The data suggest diminished hematoma expansion in the group that received earlier treatment. The subsequent large RCT, Mayer 2008,^88^ reported hematoma expansion occurring in “under 2 hours,” “under 3 hours,” and “at any time (i.e., within the four hour protocol of the study),” such that the data are not directly comparable to those of the earlier study. However, the findings suggest a similar pattern to the earlier RCT, one of diminished hematoma expansion when rFVIIa is administered earlier.

Table 22 Post-hoc evaluations of rFVIIa use in ICH before versus after 3 hours from time of symptoms onset

Article | Study Design | Dose (ug/kg) | Timing Group^*^ | Sample Size | | Mean time from onset to dosing, minutes (SD) [Range] | Mean Relative Change in ICH Volume, % (SD) [95% CI] | | | Mean Absolute Change in ICH Volume, mL (SD) [95% CI] | | | Relative Reduction in ICH Volume^, mL [95% CI]
| | | | rFVIIa | Usual Care | | rFVIIa | Usual Care | Sig | rFVIIa | Usual Care | Sig
Mayer 2005a23 | RCT | All Doses (i.e. 40, 80, 160 combined) | all pts | 287 | 94 | 167 (32) | 14 [7–21]^#^ | 29 [16–44]^#^ | p=.01 | 4.2 [2.0–6.3]^#^ | 8.7 [4.9–12.4]^#^ | p=.01 | −4.5
Mayer 2005a23 | RCT | All Doses (i.e. 40, 80, 160 combined) | <3 hrs | 199 | 68 | - | 13 | 34 | p=.004 | 4.4 | 10.7 | p=.009 | −6.3
Mayer 2005a23 | RCT | All Doses (i.e. 40, 80, 160 combined) | 3–4 hrs | 88 | 26 | - | 16 | 14 | p=0.86 | 3.8 | 3.1 | p=0.76 | 0.7
Mayer 2008^88^ | RCT | 80 | all pts | 285 | 254 | 160 (36) | 11 [6–17] | 26 [20–32] | p<.001 | 3.7 [1.7–5.7] | 7.5 [5.4–9.6] | p=.009 | −3.8
Mayer 2008^88^ | RCT | 80 | <3 hrs | 211 | 183 | - | - | - | - | - | - | - | −4.5 [−8.0 to 1.0]
Mayer 2008^88^ | RCT | 80 | <2 hrs | - | - | - | - | - | | - | - | | −5.6 [−13.1 to 2.0]

Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies.

* Timing group refers to the stratification of study patients based upon timing of treatment. For example, “<3 hrs” includes all patients who received study drug within three hours of ICH symptoms, and “3–4 hrs” includes all patients who received study drug more than 3 hours after the onset of ICH symptoms. Note that only 1 patient each in Mayer 2005^23^ and Mayer 2008,^88^ and 2 patients in Hallevi 2008^92^ received rFVIIa more than 4 hours after the onset of ICH symptoms.

^ Relative reduction in ICH volume equals the absolute change in ICH volume (mL) in the usual care group minus the absolute change in ICH volume (mL) in the rFVIIa group. A negative value indicates a smaller increase in ICH volume in the rFVIIa group than in the usual care group (i.e. favors rFVIIa), while a positive value indicates a larger increase in ICH volume in the rFVIIa group than the usual care group (i.e. favors usual care).

# 98.3% confidence interval instead of 95% confidence interval.

[underlined: Discussion.] Relative to later treatment, earlier treatment with rFVIIa may reduce hematoma growth. One drawback to our analysis is that the patients received rFVIIa within the relatively short time window of four hours. Using timing of treatment as a predictor of hematoma growth also presents analytical problems. Although it is now known that hematoma growth can continue for several hours after symptoms onset, much of ICH growth occurs prior to the baseline CT scan. Therefore, “growth” of the ICH as documented by sequential CT scans may be highly confounded by the timing of the CT scans relative to symptom onset and whether the baseline scans occur in the earliest, highest growth phase of hematoma formation or in the later, more modest growth phase. Existing studies have not explored this potential source of confounding in great detail.

Post-hoc analyses of age and other factors. Post-hoc analyses in the Mayer 2008 study posited improved functional outcomes with rFVIIa therapy when patients had a combination of younger age, lower baseline hematoma volume, and earlier rFVIIa administration. Additional post hoc analyses identified increased age and previous use of an antiplatelet agent as possible independent risk factors for thromboembolic events.88

### Comparison with Premier Database

Study patients were approximately the same age (mid 60s)and had lower mortality rates than the mortality rate of 0.34 among patients in the Premier database. Application of rFVIIa to intracranial hemorrhagein the Premier database was very low prior to 2005 but experienced a notable increase in use that year, the same year in which the first Mayer RCT23 was published (Figures 3 and 4).

### Strength of Evidence

We judged the strength of evidence grade to be moderate for all outcomes based on having four RCTs with a low risk of bias and nearly 900 patients on rFVIIa therapy. However, it is important to note that effect size estimates for all outcomes—other than arterial thromboembolic events and changes in hematoma volume—were imprecise, which precludes definitive conclusions about their effects. Another frequent component to limit the strength of evidence was inconsistency, which was due to both the variability of effect sizes and differences in direction of effect. We found no clear evidence (across any dosing level) that rFVIIa has an effect on mortality, poor modified Rankin Scale score, or venous thromboembolic events, but did find that it is associated with an increased rate of arterial thromboembolic events and a decrease in relative hematoma expansion (Table 23).

Table 23 Strength of evidence for rFVIIa use in intracranial hemorrhage

Outcome of Interest | Number of Studies | Number of Subjects | | Domains Pertaining to Strength of Evidence | | | | | | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Domains Pertaining to Risk of Bias | | | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Design | Quality | Level | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Mortality (90 day) | 4^23, 86–88^ | 944 | 384 | RCT | Good | Low | Inconsistent | Direct | Imprecise | No Effect | No | Moderate
Mortality (90 day) | 1^89^ | 24 | 30 | COBS | Fair | High | Unknown | Direct | Imprecise | No Effect | Unknown | Moderate
Arterial Thromboembolic Events | 4^23, 86–88^ | 944 | 384 | RCT | Good | Low | Inconsistent | Direct | Precise | Increase with rFVIIa | No | Moderate
Arterial Thromboembolic Events | 1^89^ | 24 | 30 | COBS | Fair | High | Unknown | Direct | Imprecise | No Effect | Unknown | Moderate
Venous Thromboembolic Events | 4^23, 86–88^ | 944 | 384 | RCT | Good | Low | Consistent | Direct | Imprecise | No Effect | No | Moderate
mRS Score | 4^23, 86–88^ | 944 | 384 | RCT | Good | Low | Inconsistent | Direct | Imprecise | No Effect | No | Moderate
Change in Hematoma Volume | 4^23, 86–88^ | 1040 | 384 | RCT | Good | Low | Inconsistent | Indirect | Precise | Decrease with rFVIIa | No | Moderate

mRS=modified Rankin Scale (validated measure of functional outcome); RCT=randomized controlled trial; RBCs=red blood cells. See Tables 4 to 7 for definitions of study quality and strength of evidence domains and designations.

### Applicability

The overall applicability of the evidence for this indication was good for treatment use in the population targeted by the RCTs—adult patients with intracerebral hemorrhage who were not on anticoagulation (Table 24). For instance, the evidence had good duration and intensity of follow-up and also encompassed a range of outcomes that included important measures of functional ability, morbidity, and mortality. The evidence is less applicable to patients on anticoagulation therapy (e.g., warfarin), who had isolated subdural or subarachnoid bleeding, or for whom surgical interventions were planned, because such patients were excluded from the RCTs. The only study to include patients on anticoagulation therapy (with subdural hemorrhage or ICH) was a small comparative observational study of fair quality, which limits applicability.

Table 24 Applicability assessment of intracranial hemorrhage studies

Available Evidence | Overall Implications for Applicability
Population
Patients presenting with CT confirmed intracerebral hemorrhage without signs of grave prognosis Mean age 65 years, male = 60 percent High mortality rate (20%) and low probability of symptom-free recovery (5%) Patients with intact clotting systems Exclusions: Patients on anticoagulation, in whom hematoma aspiration is planned, and/or who have other forms of intracranial hemorrhage (other than the small number of patients on anticoagulation and with subdural hematomas in one comparative observational study) | Gaps to applicability exist for patients on oral anticoagulation therapy (e.g., warfarin) and/or those who experience isolated subdural or subarachnoid bleeding Other approaches to intracranial bleeding may reduce the role of rFVIIa, including more aggressive management of hypertension
Intervention
Use of rFVIIa as a treatment at doses of 5 to 160 mcg/kg Deliver of rFVIIa within 4 hours of symptoms onset | Lack of clear dose-response relationships hinders applicability to dose selection decisions Difficult to interpret impact of delivery of rFVIIa earlier or later than time frame used in the studies
Comparator
Usual care via randomization | Other hemostatic agents potential comparators, but not used in this setting
Outcomes
Primary outcomes: Expansion of hematoma volume and poor modified Rankin score Secondary outcomes: thromboembolic events, mortality | Hematoma volume is a surrogate/indirect outcome that is incompletely correlated with clinical outcomes Modified Rankin score captures important information that relates to functional outcome. No meaningful outcomes omitted
Timing and intensity of follow-up
90 day follow-up for neurological status Detailed protocol for ascertainment of MI and DVT | Highly applicable with appreciation for direct, patient-centered outcomes
Setting
Multi-center international settings with likely presence of considerable heterogeneity in clinical practice | Heterogeneity may limit applicability to U.S. stroke centers

### Conclusions

For patients of mean age 65 without anticoagulation use who present for spontaneous ICH (a subset of intracerebral hemorrhage), current evidence of moderate strength suggests that neither benefits nor harms substantially exceed each other. Use of rFVIIa compared to usual care appears to attenuate hematoma growth but also increase the risk of arterial thromboembolic events without having a significant impact on mortality or functional outcome. Notably, these patients have lower rates of mortality than do patients in the Premier database. Whether patients who are on oral anticoagulation therapy, have other forms of intracranial hemorrhage (e.g., subdural or subarachnoid hemorrhage), are treated earlier with rFVIIa, are younger, have lower baseline hematoma volumes, or have no prior use of antiplatelet agents may experience better outcomes (relative to the populations already studied) remains unclear.

## Key Question 3.a. Acquired, coagulopathic massive bleeding from body trauma and comparative effectiveness of rFVIIa

### Background

Trauma is the leading cause of death in young men between the ages of 15 and 40. Hemorrhage is the leading cause of early death (within 24–48 hours) in trauma and second only to traumatic brain injury (TBI) as the overall cause of mortality.168 Hemorrhage after traumatic injury is associated with an acquired coagulopthy known as the “acute coagulopathy of trauma.”169–171 The coagulopathy develops when there is tissue injury in combination with hypotension. The severity of coagulopathy increases with increasing injury severity and is associated with worse outcomes.172 Resuscitation of these patients can worsen the coagulopathy. The dilution of blood due to rapid infusion of crystalloid, the development of hypothermia, and persistent acidosis occur during resuscitation and are known together as the “lethal triad,” which conspires to impede coagulation. Not surprisingly, the conditions which lead to the development of lethal triad are worse in cases of severe hemorrhage, particularly in those cases that require massive transfusions (most frequently defined as the use of 10 or more units of packed red blood cells (RBCs) within 24 hours of injury). This acquired coagulopathy potentiates further bleeding, which in turn leads to further physiologic derangements, increased morbidity, and increased mortality. Unfortunately, blood products that are used to replace lost blood and to treat coagulopathy can carry risks of their own. In particular, studies have highlighted increased risks of acute respiratory distress syndrome (ARDS), multiorgan failure (MOF), and sepsis with higher levels of blood product transfusions.173–175 rFVIIa has been investigated in trauma as an adjunct to control bleeding and thereby reduce the above risks.

Usual care during the time frame of included studies. As noted above, there is growing evidence of an association between coagulopathy and poor outcomes after trauma. A recent trend in the “usual care” of traumatic bleeding has been to address coagulopathy early in cases of a massive transfusion. This has been achieved by using fresh frozen plasma (FFP) earlier during the resuscitation and in greater amounts. Recent data from civilian databases and the Iraq war suggest that a 1:1 ratio of RBCs:FFP may have a survival advantage when compared to ratios closer to 4:1. In addition, some experts advocate for early transfusion of platelets as well, with a RBCs:FFP:platelet ratio of 1:1:1.^176^ As transfusing large quantities o f blood products and maintaining a high ratio of FFP to RBCs is challenging, many institutions have implemented “massive transfusion protocols.”177 These protocols faciliate coordination between the physicians and the blood bank, have been associated with improved survival, and may include include rFVIIa as part of the protocol. The studies evaluated in this section contain data on patients treated during the period of flux. Both plasma-rich transfusion practices and massive transfusion protocols were being implemented contemporaneously and after the published studies included in this section. This means that comparison to “usual care” is limited and does not necessarily reflect current practice. Two published RCTs (published in one paper) were conducted from March 2002 to September 2003,^96^ while the three comparative observational studies 97–99 evaluated data on patients treated from January 2000 to February 2005, December 2003 to October 2005, and April 2006 to August 2008, respectively. Another RCT, as of yet unpublished, was conducted from October 2005 to June 2008.

### General Characteristics of Studies of Traumatic Bleeding

For this indication, among the published literature, we identified two RCTs (both fair quality) and three comparative observational studies (all fair quality) with 267 patients who received rFVIIa for treatment use. The RCTs were two trials conducted in parallel by the same investigators and published in the same article. One of the trials enrolled patients with blunt trauma and the other with penetrating trauma.96 The two trials are evaluated separately in this review. The trials were sponsored by Novo Nordisk, and the trial statistician was an employee of the company. Another RCT was completed in June 2008 and presented at an international meeting in March 2009, but it has not yet been published.178,179 It also evaluates rFVIIa in both blunt and penetrating trauma and is sponsored by the manufacturer. Three restrospective cohort studies studies were also analyzed. They were not sponsored by the manufacturer, and the authors or statisticians were not employed by Novo Nordisk.

Place of studies within analytic framework. All of the included studies evaluated rFVIIa for treatment use (versus prophylaxis or end-stage use), as outlined in our Analytic Framework (Figure 1). However, the censoring of deaths within the first 48 hours in the randomized controlled trials96 and within 24 hours in one of the observational studies 98 raises the question of whether some end-stage use might have occurred. The RCTs reported direct outcomes (e.g., mortality, thromboembolic events) but were underpowered to detect a difference in these. Therefore, they have as their primary outcome the surrogate endpoint of RBC transfusion. The comparative observational studies all examined direct outcomes as their primary outcomes. Mortality was the primary outcome in the Rizoli and Spinella studies,97,98 and limb revascularization is the primary outcome in the Fox cohort.99

Qualitative considerations of heterogeneity. The RCTs and observational trials included both blunt and penetrating mechanisms and were from both civilian and military populations. Different anatomic mechanisms of injury often result in the final common pathways of severe tissue injury and hypotension, and these conditions are thought to drive the coagulopathy of trauma. Therefore, despite the differences in injury mechanisms, injuries of sufficient severity do share physiologic characteristics. The role of rFVIIa is to act upon these physiologic disturbances. For this reason, despite the heterogeneic mechanisms, we felt it appropriate to assess the patient populations together in this analysis.

Comparison to studies on other indications. These studies had younger patients, on average, than studies in any other adult indication. The RCTs evaluated the highest dose of rFVIIa used in any indication, although the observational studies applied much lower doses.

### Patient Characteristics and Study Design

RCTs. The two double-blind RCTs by Boffard (both published in a single paper and both fair quality (Table 14)) enrolled patients from 32 hospitals in eight countries that did not include the U.S.(namely, Australia, Canada, France, Germany, Israel, Singapore, South Africa, and the United Kingdom) and were of modest sample sizes (Table 25). Approximately 70 patients were enrolled in the rFVIIa group in each trial. Inclusion criteria included hemorrhage from a blunt or penetrating traumatic injury requiring at least six units of RBCs within four hours of hospitalization. Exclusion criteria included low GCS score (less than eight), severe base deficit (over 15 mEq/L) or acidosis (pH under 7.0). There was good baseline similarity between treatment groups. A limitation of the trials was that there were instances of missing outcomes data. For example, the primary outcome of the studies was the number of RBC units transfused. The numbers of patients for whom data was reported was lower than the number of patients who were said to have completed the trials. Another important con textual factor was the investigators’ choice to exclude from further analysis those patients who died within the first 48 hours of hospitalization, which comprised nearly 20 percent of patients in each treatment group.

Table 25 General characteristics of comparative studies of off-label rFVIIa use for massive bleeding due to body trauma

Article | Study Design | Study Setting and Time Period | Sample Size and Dose, μg/kg | Population Characteristics | | Outcomes Evaluated
| | | | Mean Age (SD) [Range] | Inclusion/Exclusion Criteria | Direct | Indirect
Boffard 2005^96^ | RCT Treatment | 32 centers Australia, Canada, France, Germany, Israel, Singapore, South Africa and UK 3/2002–9/2003 | All Rx: 139 -Blunt: 69 -Pen: 70 Usual care: 138 -Blunt: 74 -Pen: 64 Dose: 200 ug/kg after transfusion of eighth unit RBCs, followed by two 100 ug/kg doses at 1 and 3 hrs | Rx: Blunt: 33 (13) Pen: 29 (10) Usual care: Blunt: 35 (13) Pen: 32 (10) | Inclusion: -severe trauma (i.e., 6 units of RBCs transfused within 4 hrs of admission) -between 16 and 65 years old Exclusion: -cardiac arrest before trial drug administration -gunshot would to head -GCS<8 -base deficit of 15 mEq/L or pH<7.0 -transfusion of 8 units or more RBCs before arrival at trauma center -injury sustained >12 hrs before randomization | Mortality Adverse events including TE events | Transfusion requirements (e.g. RBCs, FFP) Hospital and ICU length of stay
Rizoli 2006^97,b^ | Retrospective comparative Treatment | 1 center University of Toronto Health Sciences Centre, Toronto, Canada 1/2000–1/2005 | All Rx: 38 Ucare: 204 Dose of rFVIIa is not reported | Rx: 36.8 [30.6–43.1]^CI^ Usual care: 41.1 [38.1–44.1]^CI^ | Inclusion: -traumatic hemorrhage -8 or more units RBCs during first 12 hrs of hospitalization Controls: Patients who met above inclusion criteria, but did not receive rFVIIa. | Mortality | Transfusion requirements (e.g. RBCs, FFP)
Spinella 2008^98,b^ | Retrospective comparative Treatment | Combat support hospitals in Iraq. Data from Joint Theatre Trauma Registry (JTTR) 12/2003–10/2005 | All Rx: 49 Usual care: 75 Dose: Institutional guidelines suggested 120 ug/kg | Age not reported | Inclusion: -severe trauma (i.e. ISS>15) -massive transfusion (i.e. transfusion of 10 units or more RBCs in 24 hrs) Controls: Patients who met above inclusion criteria, but did not receive rFVIIa. | Mortality Adverse events including TE events | Transfusion requirements (e.g. RBCs, FFP)
Fox 2009^99^ | Retrospective comparative Treatment | Combat support hospitals in Iraq. Data from Joint Theatre Trauma Registry (JTTR) 4/2006–8/2007 | All Rx: 41 Usual care: 12 Dose: “typically” 90–120 | Rx: 27.5 (9.4) Usual care: 24 (10) | Inclusion: -life-threatening hemorrhage (requiring > 4U PRBCs) from penetrating trauma that caused vascular injury which required repair -received damage control resuscitation (minimal crystalloid use, use of whole blood or high ratio of plasma to RBCs (<1:1.4), and liberal replacement of platelets and cryoprecipitate Exclusion: NR | Mortality Adverse events including TE events | Transfusion requirements^††^
Dutton 2004^100,†^ | Retrospective comparative Treatment | 1 University hospital USA 6/2001–12/2003 | All Rx: 81 Usual care: 32- 449^ Dose: 100 for hemorrhagic shock; 50 for congenital or pharmacologic coagulopathy | Rx: 41 (21) Usual care: NR | Inclusion: -Receipt of at least 10 units PRBCs, 8 units FFP, and 1 pheresis unit platelets (the equivalent of 1 blood volume transfusion in components), with ongoing hemorrhage and evidence of coagulopathy (abnormal PT and PTT) -Patient viability for meaningful longterm survivial as determined by institutional gatekeeper Exclusion: -Lack of patient viability | Mortality Adverse events including TE events | Transfusion requirements^††^ Hospital LOS
Harrison 2005^101,†^ | Retrospective comparative Treatment | 1 Hospital USA 2/2003–12/2003 | All Rx: 29 Usual care: 72 Dose: 60 | Rx: 41 (21) Usual care: 42 (22) | Inclusion: -Inclusion in prospectively collected trauma registry database Exclusion: -No historical matched control could be identified -Isolated closed head injury without hemorrhage -Jehovah’s witness patient who declined all transfusions | Mortality Venous TE events | Transfusion requirements †† Hospital and ICU LOS

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

CI 95% confidence interval;

U Median; Pen=penetrating; SD=standard deviation; Rx=treatment group(s); TE=thromboembolic; RBCs=red blood cells; FFP=fresh frozen plasma; ISS=injury severity scale; ICU=intensive care unit

†† Examples of transfusion requirements were red blood cells and fresh frozen plasma

a Nascimento et al.181 was used instead of Rizoli et al.97 in the harms analysis of thromboembolic events. Nascimento et al. is a continuation of Rizoli et al. with more patients.

b Perkins 2007^182^ was used instead of Spinella 2008^98^ in the harms analysis of mortality and TE events. Perkins 2007 is an overlapping non-comparative study with more patients.

^ Dutton 2004^100^ has multiple control groups. The range of sample sizes is presented.

The more recent but unpublished RCT was conducted at 100 sites in 26 countries, including 23 sites in the United States.178 It was terminated prematurely after a pre -planned interim futility analysis performed by the Data and Safety Monitoring Committee indicated that “the mortality observed in all enrolled patients was lower than expected during study design, meaning that the study as a whole would be underpowered to assess the primary endpoint [of mortality].” Therefore, “the sponsor chose to close the study.”180 Prior to terminations, the trial enrolled 468 patients with blunt trauma (221 rFVIIa, 247 placebo) and 86 with penetrating trauma (46 rFVIIa, 40 placebos). Limited data were obtained on the Clinical Trials. gov and manufacturer’s websites. These data were used for qualitative sensitivity analyses but not included in the primary analyses.

[underlined: Withdrawal of deferred informed consent]. The FDA rules for the study of emergency therapies (and similar policies in other countries) allow for deferral of informed consent.64,65 The publication of the Boffard RCTs states in the methods section, “Because of the emergency conditions and the possible absence of relatives at enrollment into the trial, waived informed consent was authorized by the ethics committees. However, whenever a patient was included without written informed consent, such consent was promptly sought from the legally authorized representative and subsequently from the patient. Adequate confirmation of consent was not obtained for six patients, and their data were excluded from analysis.”96 The publication reported that the withdrawals of deferred consent —described as “consent not confirmed” following “waived informed consent”—occurred after randomization and dosing (whether of rFVIIa or placebo), but did not note the treatment arm of the patients who withdrew. Five patients in the blunt trauma trial were withdrawn for this reason versus one patient in the penetrating trauma trial.

Comparative observational studies. The Spinella retrospective cohort study98 assessed data from a military database, the Joint Theatre Trauma Registry. Patients in this registry sustained wartime injuries in Iraq. Patients were included in the registry if they had suffered severe trauma (defined by Injury Severity Score over 15) and required transfusion of 10 or more units of RBCs within the first 24 hours of hospitalization. The time period of data collection was 2003 to 2005. Similar to the RCTs, this study excluded from further analyses those patients who had early in hospital death, although in this case, early death was defined as occurring within the first 24 hours. Among this cohort, investigators identified 49 patients who received rFVIIa and 75 who did not. The groups were relatively well matched at baseline. The authors evaluated for confounding by testing for interactions between rFVIIa use and other variables when evaluating the primary outcome of mortality at 30 days.

The second retrospective cohort study97 by Rizoli identified all trauma patients who were managed at a level I trauma center in Canada and were transfused with eight units of RBCs within the first 12 hours of hospitalization. Among this cohort, investigators identified 38 patients who received rFVIIa and 204 who did not. Groups were relatively well matched at baseline, except that the rFVIIa group received higher numbers of transfusions in the first six hours of admission. The mean time from admission to rFVIIa administration was six hours. The primary outcome was mortality at 24 hours and the secondary outcome was in-hospital mortality. Investigators used univariate analysis followed by multivariable logistic regression analysis to address issues of confounding. Importantly, investigators noted that five of the 38 patients in their cohort who received rFVIIa were also included in one of the above trauma RCTs, although the particular trial (blunt versus penetrating) was not specified.

The final retrospective cohort study by Fox,99 like the Spinella study, examined data from the Joint Theatre Trauma Registry but for patients treated during a later timeframe—from 2006 to 2007. Patients were included in the study if they suffered life-threatening vascular injuries and required transfusion of over four units of RBCs. Patients were not censored for early in-hospital death. Investigators identified 41 patients who received rFVIIa and 12 patient who did not. Groups were relatively well matched at baseline, with the possible exception of somewhat higher mean Injury Severity scores in the treatment group versus controls (29 versus 22, respectively), although this difference was not statistically significant. The authors did not evaluate for confounding.

### Intervention Characteristics

RCTs. The Boffard RCTs both used the same dosing schema consisting of three sequential infusions of rFVIIa (200,100, and 100 μ/kg) or placebo. The first dose was administered after the eighth unit of RBCs, the second one hour later, and the third three hours later. rFVIIa patients in the unpublished RCT178 received the same regimen as above, except that the first dose was given earlier during the resuscitation—after the fourth unit of RBCs. As noted above, the unpublished trial was used only for sensitivity analysis.

Comparative observational studies. In the observational studies, the exact dose of rFVIIa administered was not clear. In the Spinella study, it was noted that military guidelines recommended a dose of 120 μg/kg, but the actual drug dose administered was not reported.98 The Rizoli study97 did not report the doses of drug administered except to say that initial practice at their center was to start with a dose of 17.1 μg/kg, which was liberalized over time to higher doses, and that repeat doses were common. The Fox study99 described the doses of rFVIIa as “typically 90–120 μg/kg.” The range of rFVIIa doses administered across studies thus appears to be potentially quite broad (from 17.1 μg/kg to 120 μg/kg). In all cases, drug administration was triggered by the patient reaching a transfusion threshold that was variably defined but considered to be massive or life-threatening bleeding.

### Outcomes

Direct (patient-centered) outcomes. Results are summarized in Table 26. Dose-reponse relationships were not apparent for these outcomes.

Table 26 Mortality, thromboembolic events, and ARDS in comparative studies of rFVIIa use in body trauma

Article | Study Design/rFVIIa use | rFVIIa dose | Sample size | | Mean age (SD) | | 30-day Mortality rate | | | Thromboembolic event rate | | | ARDS rate
| | | rFVIIa | Usual care | rFVIIa | Usual care | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig
Boffard 2005^96^ (blunt arm) | RCT Treatment | 400 | 69 | 74 | 33 (13) | 35 (13) | 0.246 | 0.297 | p=.58 | 0.029 | 0.041 | NR | 0.043 | 0.162 | p=.03
Boffard 2005^96^ (penetrating arm) | RCT Treatment | 400 | 70 | 64 | 29 (10) | 32 (10) | 0.243 | 0.281 | p=.69 | 0.057 | 0.047 | NR | 0.057 | 0.078 | p=.74
Rizoli 2006^97^ | Retrospective comparative Treatment | NR | 38 | 204 | 36.8 [30.6–43.1]^CI^ | 41.1 [38.1–44.1]^CI^ | * | * | CI 0.8–7.6^*^ | NR | NR | NR | NR | NR | NR
Nascimento 2008^181^& | | - | 72 | 256 | - | - | - | - | | 0.097 | 0.063 | p=.31 | - | - | -
Spinella 2008^98^ | Retrospective comparative Treatment | 120 | 49 | 75 | NR | NR | 0.306 | 0.507 | p=.03 | 0.041 | 0 | p=.15 | 0.020 | 0.040 | p=1.0
Fox 2009^99^ | Retrospective comparative Treatment | 90–120 | 41 | 12 | 28 (9) | 24 (10) | 0.073^†^ | 0^†^ | p=1 | 0.122 | 0.083 | p=1 | NR | NR | NR
Dutton 2004^100,†^ | Retrospective comparative Treatment | 50; 100 | 81 | 32–449^ | 41(21) | NR | 0.580 | 0.438; 0.325^ | NR; p=.60^ | 0 | NR | NR | NR | NR | NR
Harrison 2005^101,†^ | Retrospective comparative Treatment | 60 | 29 | 72 | 41 (21) | 42 (22) | 0.414^**^ | 0.403^**^ | NR | 0.069^#^ | 0.197^#^ | p=0.2 | NR | NR | NR

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies.

CI 95% confidence interval;

ARDS=acute respiratory distress syndrome; NR=not reported

* This study generated odd ratios for survival using a multivariate model, which included independent predictors of in-hospital survival (baseline pH, platelet count, age, head injury (AIS), and transfusion during the resuscitation period) as covariates. Prior to modeling, the unadjusted in-hospital mortality rates were 0.500 in the rFVIIa group and 0.485 in the usual care group. In the multivariate models, rFVIIa was shown to have no significant impact on in-hospital survival (OR: 2.5, 95% CI: 0.8–7.6) but to improve 24-hour survival (OR: 3.4, 95% CI: 1.2–9.8).

& Nascimento 2008^181^ is an extension of Rizoli 2006^97^ with more patients. It also reports data on thromboembolic events not reported in the original publication.

^ Dutton 2004^100^ has multiple control groups. The range of sample sizes is presented. For purposes of outcome data, rates for the most narrow sample (n=32) and most broad sample (n=449) are given, respectively.

# Venous thromboembolic events only.

** 28-day mortality;

† 24-hour mortality

[underlined: Mortality]. All of the studies reported on mortality, but none were powered to detect differences in mortality. There were differences between studies in the exclusion from analysis of those patients who experienced “early” in -hospital death (defined to be death within 48 hours in the RCTs and 24 hours in the Spinella study), so comparisons across studies must be interpreted with caution. Among patients who survived at least 48 hours, the RCTs noted no difference in 30-day mortality, although mortality was lower in both rFVIIa groups compared to controls. In the unpublished RCT, there was also no difference in mortality rate between groups, whether measured for blunt or penetrating trauma or at 30 or 90 days.178 The Spinella study noted a significant decrease in 30-day mortality for patients who received rFVIIa and survived at least 24 hours. The Rizoli study identified a significant improvement in 24-hour mortality with rFVIIa. In-house mortality was lower after rFVIIa but was not significant. The Fox study noted no difference in mortality between groups at 24 hours. To place the mortality differences in the context of the comparable findings for the other clinical indications, also see Figure 5 (in the Key Question section on intracranial hemorrhage). (Note that the Rizoli study is not included in this figure because its findings were reported as an odds ratio rather than event rate.)

[underlined: Thromboembolic events]. Of the published studies, the Boffard RCTs and two of the retrospective trials (Spinella and Fox) evaluated thromboembolic complications. While the retrospective study by Rizoli did not report on thromboembolic complications, an extension of the study by Nascimento181 did report this. None of the studies found any difference between the rFVIIa and usual care groups for such events. However, the absolute number of events was low, so the studies were likely underpowered to detect any difference between groups. The unpublished RCT also found no differences between groups in thromboembolic event rates.178 To place the differences in thromboembolic event rates in the context of the comparable findings for the other clinical indications, see Figure 6 (in the Key Question section on intracranial hemorrhage).

[underlined: Acute respiratory distress syndrome (ARDS).] Only the Boffard RCTs and Spinella study evaluated the rate of ARDS at 30 days. The blunt trauma RCT identified a significantly lower rate of ARDS in the rFVIIa group compared to the usual care group, while the penetrating trauma RCT and Spinella study together suggested a trend in the same direction. Event rates for ARDS were low, which again raises concern that the studies did not have adequate power to detect a difference for this outcome. Of note, we did not evaluate the outcome of multi-organ failure (MOF), because it was not clear how MOF was defined in the study or if these cases overlapped with cases diagnosed with ARDS.

Indirect (surrogate) outcomes. Results are summarized in Table 27. Dose -response relationships are not apparent for these outcomes.

Table 27 RBC transfusion in comparative studies of rFVIIa use in body trauma

Article | Study Design rFVIIa use | rFVIIa dose | Sample size^*^ | | Mean age (SD) | | 24-Hour RBC transfusion, units (SD) [IQR]
| | | rFVIIa | Usual care | rFVIIa | Usual care | rFVIIa | Usual care | Sig
Boffard 2005^96^ (blunt arm) | RCT Treatment | 400 | 52 | 59 | 33 (13) | 35 (13) | 6.9 (6.2)& | 10.9 (9.3)& | p=.02&
Boffard 2005^96^ (penetrating arm | RCT Treatment | 400 | 57 | 52 | 29 (10) | 32 (10) | 4.5 (5.3)& | 7.7 (9.9)& | p=.10&
Rizoli 2006^97^ | Retrospective comparative Treatment | NR | 38 | 204 | 36.8 [30.6–43.1]^CI^ | 41.1 [38.1–44.1]^CI^ | # | # | #
Spinella 2008^98^ | Retrospective comparative Treatment | 120 | 49 | 75 | NR | NR | 16^U^ [13–27] | 14^U^ [11–19] | p=.02
Fox 2009^99^ | Retrospective comparative Treatment | 90–120 | 41 | 12 | 28 (9) | 24 (10) | NR | NR | NR
Dutton 2004^100,†^ | Retrospective comparative Treatment | 50; 100 | 81 | 32–449^ | 41(21) | NR | ^ | NR | NR
Harrison 2005^101,†^ | Retrospective comparative Treatment | 60 | 29 | 72 | 41 (21) | 42 (22) | 18.3^**^ (7.5) | 22^**^ (9.7) | p=.04

† The studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies.

CI 95% confidence interval

U Median.

* The sample size for RBC transfusions is smaller in Boffard 2005^96^ because patients who died within the 48-hour observation period for RBC transfusions were excluded.

^ Dutton 2004^100^ has multiple control groups. The range of sample sizes is presented. 24-hour transfusion results are only given for patients who received rFVIIa divided into 2 groups: “responders” who received 4.5 (SD 8.0) units RBCs and “non-responders” who received 22.6 (SD 14.7) units RBCs.

& 48 hr RBC transfusions. Mean and standard deviation was derived graphically from figure 2 in Boffard 2005^96^. P-values are based on 48-hour RBC transfusions in patients who survived at least 48 hours (blunt arm: rFVIIa group: median: 7.0 units, range: 0–29 units; usual care group: median: 7.5 units, range: 0–35 units. Penetrating arm: rFVIIa group: median 3.9 units, range: 0–30 units; usual care group: 4.2 units, range: 0–41 units). P-values were calculated using the one-sided Wilcoxon-Mann-Whitney rank test.

# This study used multivariate modeling to generate odd ratios for survival in the rFVIIa group versus control group. The model adjusted for independent predictors of in-hospital survival, which included “transfusion during the resuscitation period.” Without adjustment for differences in important baseline covariates, RBC transfusions during the first 24 hours were 24.9 units (95% CI: 21.5–28.3) in the rFVIIa group and 14.9 units (95% CI: 14.0–15.8) in the usual care group, p<.0001.

** 72-hour RBC transfusions.

RBCs=red blood cells; NR=not reported

[underlined: Red Blood Cell (RBC)transfusion]. All of the studies reported on some aspect of RBC transfusion, although comparisons across studies are difficult for this outcome because of the variable censoring of patients who experienced early in-hospital death. For patients who survived to 48 hours, the blunt trauma RCT reported a significant reduction in the 48 -hour RBC transfusion rate for patients who received rFVIIa versus controls. In the penetrating trauma RCT, there was a similar but non-significant finding of reduced RBC transfusions in the rFVIIa group. In the unpublished RCT, there were comparable findings: a significant reduction in RBC transfusions for rFVIIa patients in blunt trauma and a non-significant reduction in penetrating trauma.178 In contrast, the Spinella study identified a significant increase in transfusion requirements with rFVIIa. The Rizoli and Fox studies did not independently assess this outcome.

Consideration of poor quality comparative observational studies. Two studies which were considered to be of “poor quality” were compared with the other studies. In the studies by Dutton100 and Harrison,101 the findings on mortality, thromboembolic events, and RBC transfusions were consistent with those described above (Tables 26 and 27). Other outcomes were not reported.

### Other Considerations

Differences in baseline mortality rate. Both the Rizoli97 and Spinella98 studies suggest that the higher baseline mortality rates in the patients they studied account for the greater and significant decreases in mortality they observed compared to the Boffard RCTs.96 They also cite higher rates of markers of injury severity. For instance, both cohort studies cite higher transfusion requirements within the first 24 hours, and the Spinella study describes lower admission SBP and pH among their patients versus the Boffard RCT patients.

Possible interactions with acidosis, thrombocytopenia, and timing and era of administation. In a post-hoc subgroup analysis of the patients who received rFVIIa, the Rizoli study identified an association between patients with higher baseline pH and platelet counts and increased survival. The Spinella study found a similar post-hoc association between shorter time to intervention and increased survival. Of note, in the unpublished RCT178 patients were administered rFVIIa earlier in the resuscitation than in the published RCTs (after 4 units of RBCs versus 8 units). In addition, the trial was conducted during the time period when “usual care” more often included the use of matched transfusion ratios of RBCs to FFP (1:1) and massive transfusion protocols. This may explain why the baseline mortality rate among controls appears to be lower than it was for the Boffard RCTs.

### Comparison to Premier Database

Study patients, mean ages 28–41, were younger by 20 years, on average, than patients in the Premier database (mean age 53 years). However, mortality rates were comparable to the Premier mortality rate of 0.33. Use of rFVIIa in the Premier patients started slowly in the early 2000s, but increased sharply in 2005, the same year the Boffard RCTs were published (Figures 3 and 4).

### Strength of Evidence

The overall strength of evidence was low for all of the outcomes evaluated, including the outcome for which rFVIIa was weakly but non-significantly favored, namely ARDS. These determinations were based primarily on weaknesses in two strength of evidence domains: the “risk of bias” domain, which had ratings of a “medium” or “high” overall risk of bias for all outcomes, and the “precision” domain, which had ratings of “imprecise” for all outcomes. The rating of “imprecise” was based on wide confidence intervals for the major outcomes which in turn were due to low event rates in studies that were underpowered to detect mortality and major morbidity outcomes (Table 28).

Table 28 Strength of evidence for rFVIIa use in body trauma

Outcome of Interest | Number of Studies | Number of Subjects | | Domains Pertaining to Strength of Evidence | | | | | | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Domains Pertaining to Risk of Bias | | | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Design | Quality | Overall Risk | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Mortality (30 days) | 2^96^ | 139 | 138 | RCT | Fair | Medium | Consistent | Direct | Imprecise | No effect | Unknown | Low
Mortality (30 days) | 3^97–99^ | 128 | 279 | COBS | Fair | High | Consistent | Direct | Imprecise | Weakly favors rFVI | Unknown | Low
Thromboembolic Events | 2^96^ | 139 | 138 | RCT | Fair | Medium | Consistent | Direct | Imprecise | No effect | Unknown | Low
Thromboembolic Events | 3^98, 99, 181^ | 162 | 331 | COBS | Fair | High | Consistent | Direct | Imprecise | No effect | Unknown | Low
Units of RBCs Transfused | 2^96^ | 139 | 138 | RCT | Fair | Medium | Consistent | Indirect | Imprecise | Favors rFVIIa | Unknown | Low
Units of RBCs Transfused | 1^98^ | 49 | 75 | COBS | Fair | High | Unknown | Indirect | Imprecise | Favors Usual Care | Unknown | Low
ARDS | 2^96^ | 139 | 138 | RCT | Fair | Medium | Consistent | Direct | Imprecise | Weakly favors rFVIIa | Unknown | Low
ARDS | 1^98^ | 49 | 75 | COBS | Fair | High | Unknown | Direct | Imprecise | Weakly favors rFVIIa | Unknown | Low

ARDS=acute respiratory distress syndrome; RBCs=red blood cells; RCT=randomized controlled trial; COBS=comparative observational study. See Tables 4 to 7 for definitions of study quality and strength of evidence domains and designations.

### Applicability

The overall applicability of the evidence was fair for treatment use in the population targeted—adult patients with blunt or penetrating trauma who were not censored for early in hospital death (defined as 24 hours or 48 hours, depending on the study). Specifically, the types of trauma and practice settings represented by the evidence likely have good applicability to major trauma centers in the U.S., as well as combat settings experienced by U.S. troops. On the other hand, the “usual care” of such patients has likely changed at least moderately since the studies were conducted (e.g., with the introduction of massive transfusion protocols and 1:1 transfusion ratios for RBCs:FFP). The applicability of the mortality outcomes is also difficult to interpret given the censoring of patients who experienced early in-hospital mortality. Finally, the follow-up of 30 days may be insufficient to judge applicability to general practice (Table 29).

Table 29 Applicability assessments of studies of body trauma

Available Evidence | Overall Implications for Applicability
Population
Patients presenting bleeding secondary to blunt or penetrating trauma requiring massive transfusion of RBCs (variably defined) prior to rFVIIa dose Patients with coagulopathy of trauma Mean age 32 Exclusions: In several studies, patients who died within 24h or 48h (censoring point varies with study) or with symptoms/signs indicating grave prognosis | The population included may be infrequent in clinical practice, especially outside of major regional referral centers for trauma. Community practice may involve greater use of rFVIIa as end-stage therapy in patients with poor prognosis
Intervention
As series of treatment doses of 200, 100 and 100 mcg/kg during treatment for trauma Transfusion protocol in place at most sites | RCT dose is relatively high compared to other studies
Comparator
Usual care via randomization or matched controls Studies implemented prior to current consensus regarding 1:1 ratio of transfusion products and implementation of institutional massive transfusion protocols | Other prophylactic hemostatic agents potential comparators, but not used in this setting Usual care has likely changed moderately since the studies were conducted.
Outcomes
Primary outcomes: RBC transfusion requirements in RCTs (over 48 hours) and patient mortality Secondary outcomes: thromboembolic events, ARDS | Surrogate/indirect outcomes without necessary link to clinical outcomes Mortality outcomes less applicable due to censoring (need to survive 24h or 48h post-trauma (censoring point varies with study)) Insufficient sample size to meaningfully assess other clinical outcomes Quality of life or functional status measures absent
Timing and intensity of follow-up
Follow-up for duration of hospitalization, one COBS with 30-day mortality information Detailed protocol for ascertainment of MI and DVT | Longer term outcomes desirable
Setting
Highly specialized trauma centers in Australia, Canada, France, Germany, Israel, Singapore, South Africa, and U.K., as well as a combat support hospital in Iraq | Experience likely similar to specialized U.S. trauma centers, but some cross-national differences likely exist, and military hospitals may also differ from civilian ones

### Conclusions

The available evidence has low strength and does not permit definitive conclusions regarding the impact of rFVIIa use compared to usual care. The two RCTs, in blunt and penetrating trauma and with mean ages of 29 to 33 years old, reported no improvement in mortality with rFVIIa. However, the conclusions which can be drawn from this are limited by their lack of power for evaluating mortality and the censoring of deaths which occcured within the first 48 hours. One observational study found a significantly reduced death rate with treatment, while the other had non-significant findings in the same direction. For acute respiratory distress syndrome, the blunt trauma RCT demonstrated a significant reduction for rFVIIa patients, while across the remaining two studies that evaluated this outcome(the penetrating trauma RCT and one observational study)there was a trend in the same direction. There was no evidence of an increase in thromboembolic harm with treatment, but again the strength of evidence for this outcome was low. Thus, current evidence of low strength suggests the potential for benefit and no evidence of harm. Importantly, the patient s were younger in the studies than in the Premier database, but nonetheless had similar mortality rates. The importance and nature of interactions between outcomes and the era of rFVIIa administration remain unclear, as does the relationship between outcomes and the timing of rFVIIa administration or baseline levels of acidosis or thrombocytopenia.

## Key Question 3.b. Bleeding from brain trauma and comparative effectiveness of rFVIIa

### Background

Traumatic brain injury (TBI) is the leading cause of overall death and disability after trauma.183 In severe cases, mortality rates are as high as 30–50 percent.184 Bleeding within the brain parenchyma is a significant contributor to these poor outcomes. The mechanisms are complex and poorly understood but differ in important ways from spontaneous ICH, which typically consist of more localized areas of bleeding at sites of prior atherosclerotic or thrombotic injury. In the presence of the coagulopathy of trauma,155 it is more likely that injured parenchyma, and even non-injured parenchyma, will become ischemic. Medical management includes optimization of cerebral blood flow and oxygen delivery. Surgical evacuation for large hemorrhagic lesions secondary to TBI is the only existing treatment for large bleeds (when decompression must be performed to relieve increased intracranial pressure), but often can not be attempted expeditiously secondary to the presence of concurrent coagulopathy, whether due to the trauma itself or the need for resuscitation fluids for hemorrhage at other regions of the body. Of note, TBI is a well-established risk factor for the development of deep vein thrombosis (DVT).

Usual care during the time frame of included studies. The changes in approach to treatment of coagulopathy noted in the above section on body trauma also apply to patients with TBI. Patients with bleeding due to TBI are now recognized to have similar problems with the coagulopathy of trauma.185 There is growing understanding within the field regarding the need to address this coagulopathy early in the course of therapy. In addition, new evidence suggests that patients with bleeding from TBI experience significant hematoma expansion within the first 24 hours of injury and that this expansion contributes to subsequent morbidity and mortality.186,187 However, specific interventions to ameliorate this expansion have not been systematically studied in the TBI literature or have not been shown to help. For example, an RCT of plasma (FFP) use in TBI found that treatment was associated with increased mortality.188 For large hematomas, the only widely available current therapy is neurosurgical evacuation. But coagulopathy must be corrected prior to surgery, which is accomplished by plasma infusions that may be high in volume and poorly tolerated by older patients or those with cardiac dysfunction. 107 Thus, any therapy that can address TBI-associated coagulopathy and allow for earlier neurosurgical intervention—while also limiting or stopping hemorrhage—is eagerly sought.

### General Characteristics of Studies of Traumatic Bleeding

On this topic, we identified one RCT (fair quality) and one comparative observational study (fair quality), which together had 79 patients who received rFVIIa. The RCT, Narayan 2008, both was sponsored and had one author employed by the manufacturer of rFVIIa.106 The comparative observational study selected for inclusion was the earlier of two published by Stein and colleagues with overlapping patient populations. While the latter cohort study189 included more patients, these patients were more likely to have significant concurrent trauma elsewhere at the body and were less well matched to controls at baseline. The retrospective cohort chosen for inclusion, Stein 2008, was not sponsored and had no authors or statisticians employed by the manufacturer.107 The full Stein 2008 cohort study included some patients with traumatic injuries at areas of the body other than the brain, but also performed subgroup analyses on patients with isolated TBI (Table 30). We evaluated the data on the patients with isolated TBI -associated bleeding, and when evaluated in this light, the study quality was determined to be fair, with good baseline matching of groups.

Table 30 General characteristics of comparative studies on off-label rFVIIa use for bleeding due to brain trauma

Article | Study Design | Study Setting and Time Period | Sample Size and Dose, ug/kg | Population Characteristics | | Outcomes Evaluated
| | | | Mean Age (SD) [Range] | Inclusion/Exclusion Criteria | Direct | Indirect
Narayan 2008^106^ | RCT Treatment | 38 centers Canada, Finland, Germany, India, Israel, Italy, Singapore, Spain, Switzerland, and Taiwan 8/2004–5/2006 | All Rx: 61 −40: 12 −80: 11 −120: 14 −160: 12 −200: 12 Ucare: 36 | All Rx: 51.5 (21.5) Ucare: 51.4 (19.5) | Inclusion: -clinical evidence of traumatic intracranial hemorrhage on admission CT scan -GCS 4–14^*^ -contusion volume of at least 2 mL on baseline CT within 6 hrs of injury^*^ -trial drug administration within 2.5 hrs of baseline CT Exclusion: -penetrating head or spinal cord injury -life expectancy of less than 24 hrs at hospital admission -planned surgical evacuation of hematoma within 24 hrs after dosing -isolated SAH, IVH, or subdural hematomas -significant cardiovascular disease -history of hypercoagulability or thromboembolism -current anticoagulant use | Mortality Adverse events including TE events | Change in hematoma volume (relative and absolute)
Stein 2008^107^ | Retrospective comparative Treatment | 1 center University of Maryland School of Medicine, Baltimore, MD, USA 7/2002–6/2006 | All Rx: 18^#^ Ucare: 17^#^ Dose range: 8–140 ug/kg | Rx: 39.9 (25.3) Ucare: 38.1 (19.8) | Inclusion: -severe TBI (GCS<9, AIS>3) -coagulopathic at admission (INR>1.4) -deemed appropriate for neurosurgical intervention at admission Controls: Patients who met above inclusion criteria, but did not receive rFVIIa. | Mortality TE events | Time to neurosurgical intervention ICU and hospital length of stay
Tawil 2008^108,†^ | Retrospective comparative Treatment | 1 center University of New Mexico, Albuquerque, New Mexico, USA 1/2004–12/2005 | All Rx: 31 Ucare: 353 Dose is not reported | Age for Rx and Ucare combined: 36 [11–90] | Inclusion: -severe traumatic brain injury defined as GCS<9 and brain Abbreviated Injury Scale (AIS)>2 -survival>24 hours Exclusion: -diffuse cerebral infarction due to hypoperfusion -primary cerebrovascular accident -stroke secondary to angiographic complications | Cerebral infarction (odds ratio only)

† This study did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but is included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

* Original inclusion criteria for the first 8% of patients in Narayan 2008^106^ required GCS scores of 4–13, minimum contusion volume of 5 mL, and time from injury to CT scan of 4 hours.

# Data is for patients with isolated traumatic brain injury only.

SD=standard deviation; Rx=treatment group(s); Ucare=usual care; TE=thromboembolic; GCS=glasgow coma scale; TBI=traumatic brain injury; AIS=abbreviated injury scales; SAH=subarachnoid haemorrhage; IVH=intraventricular hemorrhage; INR=international normalized ratio.

Place of studies within analytic framework. The two included studies of brain trauma evaluated rFVIIa for treatment use (versus prophylaxis or end-stage use, which are other potential uses, as outlined in our Analytic Framework (Figure 1)). While the Narayan RCT106 did not define its primary outcome, it reported on important direct outcomes (e.g., mortality, thromboembolic events) but was likely underpowered for these. It also reported on the indirect outcome of change in hematoma volume. The Stein comparative observational study107 did not define a primary outcome but did examine a number of different direct (e.g., mortality, thromboembolic events) and surrogate (e.g., time to neurosurgical intervention, ICU length of stay) endpoints.

Qualitative considerations of heterogeneity. As noted above, we identified one important source of potential heterogeneity among studies as the inclusion of patients with significant body trauma (as well as brain trauma) among the study population. We addressed this concern by confining our assessment to studies or sub-groups of studies that effectively excluded such patients by focusing primarily on hemorrhage from isolated TBI.

Comparison to studies on other indications. The populations in these studies were young compared to most of the non-trauma studies in adults for other indications, with mean age in the Narayan RCT of 51 in both groups and 45–50 in the Stein cohort study. The rFVIIa dose range of 40–200 μg/kg in the RCT and 8–140 μg/kg in the cohort study were in the low to middle range of those used for rescue treatment across indications.

### Patient Characteristics and Study Design

RCTs. The Narayan 2008 RCT was a fair quality dose-finding and safety trial with small sample sizes: 36 patients in the usual care group and 61 patients in the aggregate rFVIIa group (divided relatively evenly between five dosing groups containing an average of 12 patients per group).106 It was conducted at 38 hospitals in 10 countries, but not the U.S. Inclusion criteria included intracranial hematoma volume of at least two mL, baseline CT scan within six hours of injury, and administration of trial drug within 2.5 hours of baseline CT scan. Important exclusion criteria included known vitamin K antagonist use and planned neurosurgical intervention within 24 hours of admission. There was acceptable baseline similarity between groups among the patients, blinding of the two radiologists who independently evaluated the CT scans for hematoma size and growth, and no loss to follow-up at day 15, the endpoint of the trial. The most problematic aspect of study design was the extremely low enrollment rate of four percent of those screened, which might have been even lower if the investigators had not amended their protocol mid-way to change the minimum lesion volume size required for enrollment from five mL to two mL. The primary outcome was not defined, but the study states that its focus was on “safety endpoints,” namely those of thromboembolic complications (including DVT) and mortality at 15 days.

Comparative observational study. The Stein 2008 retrospective cohort study evaluated patients from the trauma registry of the Shock Trauma Center at the University of Maryland.107 Patients were included if they were found to have “severe” TBI (defined at a GCS score under nine and an abbreviated Injury Severity Score of four or five) and coagulopathy (defined as INR greater than or equal to 1.4), and were “deemed appropriate for immediate neurosurgical intervention” at the time of hospital admission. Patients who received vitamin K antagonists such as warfarin were included in the study. Among this cohort’s subgroup of patients with isolated TBI, which is the focus of our evaluation, there were small sample sizes: 18 patients received rFVIIa and 17 received usual care. These groups were well-matched at baseline, with the possible exception of a higher rate of pre-injury warfarin use in the rFVIIa group. Investigators did not perform any statistical analyses to evaluate or adjust for residual confounding. One limitation of the study design relates to the determination at the time of admission of appropriateness for immediate neurosurgical intervention, which was not further defined in the paper. The primary outcome was time to neurosurgical intervention, the only widely available definitive therapy for large bleeds. The paper also reported on mortality and thromboembolic events.

### Intervention Characteristics

RCT. The RCT intervention group received single doses of rFVIIa (40, 80, 120, 160, or 120 μg/kg), while controls received placebo, delivered within 2.5 hours of the baseline CT scan. No repeat doses were given.

Comparative observational study. The vast majority of patients who received rFVIIa were administered a single dose but the doses varied widely from 8 to 140 μg/kg. The dose was apparently determined by the choice to administer the entire 1.2 mg vial in which the rFVIIa is packaged, rather than by a weight-based calculation for a given patient. It is unclear at what time in the hospital course rFVIIa was delivered, but as neurosurgical intervention occurred within a mean of 185 minutes from arrival, rFVIIa was clearly given within a mean time of less than that amount.

### Outcomes

Direct (patient-centered) outcomes. Summary results are reported in Table 31.

Table 31 Mortality, thromboembolic events, and absolute change in hemotoma volume in comparative studies of rFVIIa use in brain trauma

Article | Study Design/rFVIIa use | rFVIIa dose | Sample size | | Mean age (SD) [Range] | | Mortality rate | | | Thromboembolic event rate^*^ | | | Absolute change in hematoma volume, mL (SD)
| | | rFVIIa | UC | rFVIIa | Usual care | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig
Narayan 2008^106^ | RCT Treatment | 40 80 120 160 200 | 12 11 14 12 12 | 36 | All Rx: 51.5 (21.5) | 51.4 (19.5) | 0 0 0.071 0.167 0.333 | 0.111 | NR | 0.167 0.182 0.214 0 0.167 | 0.083 | NR | 11.8 (13) 5.0 (5.3) 8.9 (17.7) 3.9 (10.4) 4.9 (13) | 10.4 (25) | p=.96 p=.38 p=.96 p=.27 p=.86
Narayan 2008^106^ | All Patients | | 61 | 36 | 51.5 (21.5) | 51.4 (19.5) | 0.115 | 0.111 | NR | 0.148 | 0.083 | 3.3 [0.69–16.2]^ | 7.0 (12.9) | 10.4 (25) | p=0.48
Stein 2008^107^ | Retrospective comparative Treatment | Range: 8–140 | 18^#^ | 17^#^ | 49.8 (26.9) | 44.8 (20.6) | 0.333 | 0.529 | p=0.24 | 0.222 | 0.176 | p=0.74 | NR | NR | NR
Tawil 2008^108,†^ | Retrospective comparative Treatment | NR | 31 | 353 | Age for Rx and Ucare combined: 36 [11–90] | | NR | NR | NR | higher^**^ | ** | 3.1 [1.1–8.0]^**^ | NR | NR | NR

† This study did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but is included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies.

* Thromboembolic event rates were calculated by dividing the number of thromboembolic events by the sample size, not the number of patients who experienced thromboembolic events. Therefore, the rates reported here may differ slightly from those reported in each study. The tests of statistical significance presented are those reported by the individual studies and are not based upon the thromboembolic event rates reported in this table.

# Data are for patients with isolated traumatic brain injury only.

^ Odds ratio and 95% confidence interval.

** Odds ratio and 95% confidence interval. Multivariate analyses demonstrate higher adjusted odds ratio of cerebral infarction with rFVIIa treatment.

Rx=treatment; NR=not reported; SD=standard deviation; Rx=treatment group

[underlined: Mortality]. The Narayan 2008 RCT reported no difference between groups in mortality at 15 days, with rates of 11 percent in each group (seven of 61 in the combined rFVIIa group, four of 36 in the usual care group). The Stein 2008 cohort study did not clearly define the length of follow-up for the patients, but this is likely equal to the hospital length of stay (LOS) given the retrospective nature of the study. The mean hospital LOS was 14.6 days and 19.1 days for the rFVIIa and usual care groups, respectively, which is roughly equivalent to the 15-day follow-up time of the RCT. Among patients with isolated TBI, the Stein cohort identified a reduced mortality with rFVIIa compared to usual care but this was a non-significant finding: 33.3 percent (6 of 18) versus 52.9 percent (9 of 17) in the two groups, respectively. The findings in both studies are limited by low event rates. To place the mortality differences in the context of the comparable findings for the other clinical indications see Figure 5 above (in the Key Question section on intracranial hemorrhage).

[underlined: Thromboembolic events]. Event rates are also low for thromboembolic outcomes. Across the studies there was a trend toward higher rates of thromboembolic events in the rFVIIa group compared to usual care group. In the Narayan RCT the event rates were 16.4 percent (10 of 61) in the rFVIIa group versus 5.6 percent (2 of 36) in the usual care group. Five of the 10 events in the rFVIIa group consisted of DVTs, all of which were symptomatic. In the Stein cohort study the event rates were 22.2 percent (4 of 18) in the rFVIIa group versus 17.6 percent (3 of 17) in the usual care group. The one DVT among these occurred in the usual care group. To place the differences in thromboembolic event rates in the context of the comparable findings for the other clinical indications, see Figure 6 above (in the Key Question section on intracranial hemorrhage).

Indirect (surrogate) outcomes. Summary results are reported in Table 31.

[underlined: Hematoma expansion]. Only the Narayan 2008 RCT reported on hematoma change at 24 hours, which it defined as the mean volume change in hematoma size from baseline. Of note, baseline hematoma volume was well-matched at 11.3 mL (SD 10.9) in the combined rFVIIa group and 10.4 mL (SD 10.8) in the usual care group. The study noted a non-significant reduction in expansion in the rFVIIa group compared to controls (7.0 mL (SD 12.9) versus 10.4 mL (25.0), respectively).

[underlined: Time to neurosurgical intervention]. Only the Stein cohort study evaluated this outcome, which was its primary outcome. The study found that, with treatment, there was a significant decrease in absolute minutes to neurosurgical intervention: 185.3 (SD 219.9) for the rFVIIa group versus 518.6 (SD 409.8) for the usual care group (p=0.005).

Consideration of poor quality comparative observational study. In the poor quality comparative observational study by Tawil,108 the findings on thromboembolic events are consistent with those described above (Table 31). Other outcomes were not reported.

### Other Considerations

Possible interactions with coagulopathy, CHF, or blunt trauma injuries to the cerebral vasculature. The Stein cohort study enrolled only patients with baseline derangements in laboratory markers of coagulopathy, defined as INR equal to or greater than 1.4. While the Narayan RCT had no comparable inclusion criteria, it performed post hoc analyses of the subgroup of patients with platelets less than 100K, PT > 14, aPTT > 45 seconds, or INR > 1.2 (13 rFVIIa, 8 placebo). These analyses note a difference between groups, favoring rFVIIa, in the degree of hematoma expansion but are based on small sample sizes. Another subgroup that the Stein study proposed may have the potential for greater benefit from rFVIIa are those patients who have poor toleration of large volume infusions (e.g., the elderly and those with congestive heart failure (CHF)) and yet require rapid correction of coagulopathy to allow for neurosurgical intervention.107

Other authors have raised concerns regarding a subgroup of patients who might have the potential for increased harm with rFVIIa administration.108 These are patients who have experienced blunt trauma to the cerebral vessels and thus may already be at increased risk for post-traumatic cerebral infarction, a well recognized complication of TBI.190 Limited cohort study data suggest that rFVIIa administration to this group of patients may increase the risk of post-traumatic cerebral infarction even further.108

### Comparison to Premier Database

Study patients, with mean ages 36–52, were younger by 15–20 years, on average, than patients in the Premier database (mean age 63 years). Those in the Stein cohort study experienced a mortality rate comparable to the rate of 0.34 in the Premier database, but the RCT patients had a lower mortality rate than either of these. The Premier database indicated a low level of rFVIIa use for brain trauma in the early 2000s but, similar to the intracranial hemorrhage and body trauma indications, there was an increase in use in 2005 and a possible leveling off more recently (Figure 19).

Figure 19 Premier database rFVIIa use in intracranial hemorrhage and trauma of the body and brain

Figure 19 depicts the Premier database rFVIIa rise in intracranial hemorrhage and trauma of the body and brain, 2000- 2008. The Premier database indicated a low level of rFVIIa use for brain trauma in the early 2000s but, similar to the intracranial hemorrhage and body trauma indications, there was an increase in use in 2005 and a possible leveling off more recently.

### Strength of Evidence

The strength of evidence assigned to all outcomes was low, on the basis of determinations of a medium to high risk of bias for all study types (driven by the uniformly “fair” quality scores) and imprecise estimates of effect. The imprecision of effects for the direct morbidity and mortality outcomes was driven by the low event rates for these outcomes—or in the case of change in hematoma volume, a small absolute effect size—among small patient populations, suggesting that these studies were underpowered for these outcomes (Table 32).

Table 32 Strength of evidence for rFVIIa use in brain trauma

Outcome of Interest | Number of Studies | Number of Subjects | | Domains Pertaining to Strength of Evidence | | | | | | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Domains Pertaining to Risk of Bias | | | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Design | Quality | Overall Risk | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Mortality (15 days) | 1^106^ | 61 | 36 | RCT | Fair | Medium | Unknown | Direct | Imprecise | No Effect | Unknown | Low
Mortality (15 days) | 1^107,*^ | 18 | 17 | COBS | Fair | High | Unknown | Direct | Imprecise | No Effect | Unknown | Low
Thromboembolic Events (72 hours) | 1^106^ | 61 | 36 | RCT | Fair | Medium | Unknown | Direct | Imprecise | No Effect | No | Low
Thromboembolic Events (72 hours) | 1^107,*^ | 18 | 17 | COBS | Fair | High | Unknown | Direct | Imprecise | No Effect | Unknown | Low
Glasgow Coma Scale (15 days) | 1^106^ | 61 | 36 | RCT | Fair | Medium | Unknown | Direct | Imprecise | No Effect | Unknown | Low
Glasgow Coma Scale (15 days) | 1^107,*^ | 18 | 17 | COBS | Fair | High | Unknown | Direct | Imprecise | No Effect | Unknown | Low
Hematoma Volume Change | 1^106^ | 61 | 36 | RCT | Fair | Medium | Unknown | Indirect | Imprecise | No Effect | Unknown | Low

* Includes only those patients in this study with isolated traumatic brain injury

RCT=randomized controlled trial; COBS=comparative observational study

See Tables 4 to 7 for definitions of study quality and strength of evidence domains and designations

### Applicability

The overall applicability is fair for treatment use in the population targeted —patients with intracranial hemorrhage seconday to TBI, most of whom were not on anticoagulation (Table 33). The population applicability of both included studies is only fair. The Narayan RCT was limited by the small percent of patients screened who were ultimately enrolled (four percent), just as the data we evaluated from the Stein cohort was limited, in our analysis, by the inclusion of only those patients with isolated TBI rather than those with both TBI and body trauma, the latter of which is a more common pattern of injury. Another important limitation to applicability derives from the small sample sizes, which preclude meaningful determinations regarding the most direct measures of morbidity and mortality. Similarly, while the studies made admirable attempts at ascertainment of thromboembolic harms, their follow-up of 15 days is likely insufficient to make important determinations regarding the long-term health ramifications of rFVIIa therapy. Finally, the study settings at specialized trauma centers in multiple countries are likely comparable to trauma centers in the U.S.

Table 33 Applicability assessment of studies on brain trauma

Describe Available Evidence | Describe Overall Implications for Applicability
Population
Patients experiencing traumatic brain injury with CT confirmed hematoma > 2 cc (initially set at 5 cc) Includes subdural and subarachnoid hemorrhage, as well as intracerebral hemorrhage Patients primarily with intact clotting systems Mean age 50 Exclusions: Most patients on anticoagulation | The population included may be infrequent in clinical practice, especially outside of major regional referral centers for trauma As with non-traumatic causes of intracranial hemorrhage, other advances may make rFVIIa less important in the future
Intervention
A single treatment dose of 40 to 200 mcg/kg upon confirmation of intracranial hemorrhage Usual care, including transfusion protocol | Lack of apparent dose-response relationship reduces possible guidance on dose selection
Comparator
Usual care via randomization or matched controls | Other prophylactic hemostatic agents potential comparators, but not used in this setting
Outcomes
Primary outcomes: Time to neurosurgical intervention Secondary outcomes: mortality, thromboembolic events, hematoma volume change, GCS score | Surrogate/indirect outcomes related to process of care without direct link to clinical outcomes Insufficient sample size to meaningfully assess clinical outcomes
Timing and intensity of follow-up
Follow-up for 15 days after injury Had detailed protocol for ascertainment of thromboembolic events in the RCT | Longer term outcomes desirable
Setting
Highly specialized trauma centers in Canada, Germany, Israel, Finland, Italy, Switzerland, Taiwan and Singapore, and Baltimore, MD | Likely applicable to similar U.S. trauma centers despite some variations in practice

### Conclusions

Current evidence of low strength is too limited to compare the harms and benefits of rFVIIa versus usual care for intracranial bleeding due to brain trauma. The lone RCT identified no difference in mortality, while the one cohort study identified a non-significant reduction with rFVIIa treatment. There was a trend across the two studies toward increased thromboembolic events with therapy. The cohort study found a significant reduction in time to neurosurgical intervention. Across studies, event rates for mortality and thromboembolism were low, and there was low strength of evidence for all effect estimates. Study patients were younger than those in the Premier database, and compared to Premier patients, those in the RCT had a lower mortality rate, while those in the cohort study had a comparable mortality rate. The importance and nature of interactions between rFVIIa administration and coagulopathy, congestive heart failure, or blunt trauma injuries to the cerebral vasculature remain unclear.

## Key Question 4.a. Liver transplantation and comparative effectiveness of rFVIIa

### Background

Liver transplantation is associated with considerable, and in some cases massive, blood loss, not the least because the patients who undergo surgery have significant chronic, acquired coagulopathies related to their advanced liver disease. They often require intraoperative transfusions to correct for the coagulopathies and surgical blood loss. Such transfusions are associated with increased rates of post-operative mortality, multi-organ dysfunction, and infection, as well as reduced graft survival.191–194 The use of prophylactic rFVIIa at the initiation of surgery was investigated for its potential to lower the number of intraoperative transfusions required, thereby ameliorating some of these risks. However, there were concerns about rFVIIa increasing the risk of clotting at unforeseen and unwelcome sites. For instance, thrombosis of the hepatic vessels is a well-recognized complication of liver transplantation that can be devastating.195 Hepatic artery thombosis occurs in approximately five percent of transplantations, generally early after transplantation, and results in graft failure.

Usual care during the time frame of included studies. Over the past 10 years, the average transfusion requirement during liver transplantation has decreased dramatically.196 Much of this change has been attributed to advances in surgical and anesthetic technique, improved understanding and management of coagulopathy, and recognition of the significant risks associated with transfusions that are described above.197 Although wide variation between centers still exists, the current median RBC transfusion requirement per transplantation is estimated to be less than five units. This compares to a median of 20 or more units in the past. A small but growing proportion of patients is now surviving liver transplantation without the transfusion of any blood products.198

Jehovah’s Witnesses as a special population. For religious reasons, Jehovah’s Witnesses refuse the transfusion of blood products (whole blood, red blood cells, white blood cells, platelets, and plasma). However, the religion enjoins its members to make personal determinations regarding the appropriateness of infusion of blood fractions such as cryoprecipitate, recirculated autologous blood, cell-saved blood, albumin, and recombinant products, which some Jehovah’s Witness patients will accept. The first liver transplantation in a Jehovah’s Witness patient occurred in 1994.^199^ But there have been a growing number since that time, and the challenge of these are discussed in the transplantation literature.200,201 Usual care in these patients can include pre-operative use of recombinant erythropoietin and intra-operative use of recirculated autologous and cell-saved blood, aprotinin, cryoprecipitate, and albumin. Products that minimize blood loss in such patients are eagerly sought and may change their risk-benefit ratio of transplantation.

### General Characteristics of Studies of Bleeding in Liver Transplantation

We identified four RCTs (two fair quality, two poor quality) and one comparative retrospective cohort study (fair quality) that examined the prophylactic use of rFVIIa in 215 liver transplant recipients (Table 34). The RCTs by Planinsic111 and Lodge 110 both had authors employed by the manufacturer of rFVIIa. The RCTs by Pugliese112 and Liu 113 reported no financial ties to the manufacturer. The comparative observational study by Hendriks 114 had one author employed by the manufacturer.

Table 34 General characteristics of comparative studies on off-label rFVIIa use for liver transplantation

Article | Study Design | Study Setting/Time Period | Sample Size/Dose (μg/kg) | Population Characteristics | | Outcomes Evaluated
| | | | Mean Age (SD) [Range] | Inclusion/Exclusion Criteria | Direct | Indirect
Lodge 2005^110^ | RCT Prophylaxis | 14 centers 8/2001–9/2003 | All Rx: 121 60*: 63 120*: 58 Ucare: 61 *rFVIIa patients received between 3 and 6 doses | Rx: 60: 53.3 (11.2) 120: 52.6 (9.2) Ucare: 52.3 (11.5) | Inclusion: -undergoing OLT -cirrhosis (Pugh class B or C) -over 18 years old Exclusion: -previous liver transplantation -split liver transplantation -scheduled multiorgan transplantation -scheduled living related-donor transplantation -renal insufficiency requiring dialysis -documented coagulation disorder -history or presence of portal vein thrombosis | Mortality Adverse events including TE events | Transfusion requirements^††^ Hospital and ICU length of stay
Planinsic 2005^111^ | RCT Prophylaxis | 9 centers 2/2000–9/2000 | All Rx: 64 20: 18 40: 24 80: 22 Ucare: 19 | Rx: 20: 49.4 (13.4) 40: 49.7 (10.1) 80: 51.9 (8.8) Ucare: 49.9 (11) | Inclusion: -undergoing OLT -cirrhosis (Pugh class B or C) -over 18 years old Exclusion: -previous liver transplantation -split liver transplantation -scheduled multiorgan transplantation -scheduled living related-donor transplantation -renal insufficiency requiring dialysis -documented inherited coagulation disorder -history or presence of portal vein thrombosis | Mortality Adverse events including arterial TE events | Transfusion requirements^††^
Pugliese 2007^112^ | RCT Prophylaxis | 1 center Rome, Italy 11/2003–7/2004 | All Rx: 10 Ucare: 10 Dose: 40 ug/kg | Age not reported. | Inclusion: -OLT -Hb>8 mg/dL, INR>1.5, fibrinogen>100 mg/dL | Mortality Adverse events including TE events | Transfusion requirements^††^ Blood loss Operating time Hospital and ICU LOS
Liu 2009^113^ | RCT Prophylaxis | 1 center Guangzhou, China 3/2003–7/2006 | All Rx: 14 Ucare: 14 Dose: 70–80 ug/kg | Rx: 51.9 [36–54] Ucare: 47.5 [41–65] | Inclusion: -OLT | TE events | Blood loss Operating time
Hendriks 2001^114^ | Prospective comparative Prophylaxis | 1 center Netherlands 12/1998–9/1999 | All Rx: 6 Ucare: 12 Dose: 80 ug/kg | Rx: 43^U^ [37–61] Ucare: 48^U^ [34–63] | Inclusion: -undergoing OLT -cirrhosis (Pugh class B or C) -over 18 years old Exclusion: -“overt major bleeding” -known hereditary bleeding disorder -history of venous or arterial thrombosis -clinically overt atherosclerosis -renal insufficiency (serum creatinine>1.7 mg/dL) -fulminant hepatic failure -use of NSAIDs within 2 weeks of transplantation Controls: Historical and contemporary controls (11/1997–9/1999) matched 2:1 on year of transplantation, Child-Pugh classification, and urea nitrogen levels. These covariates were previously identified by the authors to be independent predictors of transfusion requirements. | Adverse events including TE events | Transfusion requirements^††^ Operating time
De Gasperi 2005^115,†^ | Retrospective comparative Prophylaxis | 1 center Milan, Italy 2/2003 | All Rx: 6 Ucare: 6 Dose: 20 ug/kg at the start of surgery. Additional 20 ug/kg 30–40 minutes after reperfusion for significant bleeding. | Rx: 45 (4) Ucare: 47 (9) | Inclusion: -OLT | Mortality | Transfusion requirements^††^ Blood loss
Kalicinski 2005^116,†^ | Retrospective comparative Prophylaxis | 1 center Poland Time period not reported. | All Rx: 28 Ucare: 61 Mean dose: 51.5 ug/kg; Range: 30–100 ug/kg | Rx: 13.2 (4.2) Ucare: 11.3 (5.6) | Inclusion: -OLT from cadaveric donor Exclusion: -patients receiving retransplants or transplants from living related donors | Mortality Adverse events including TE events | Transfusion requirements^††^ Operating time Hospital and ICU LOS
Niemann 2006^117,†^ | Retrospective comparative Prophylaxis | 1 center University of California, San Francisco, CA, USA 2000–2004 | All Rx: 11 Ucare: 11 Mean dose: 58 ug/kg, SD=18 ug/kg | Rx: 48 (15) Ucare: 41 (17) | Inclusion: -OLT in adult patients with MELD score>20 and PT>1.5–2 times normal control Exclusion: -Re-transplantation or combined transplantation -rFVIIa given within 24 hours prior to surgery or given during surgery but >30 minutes from incision | Mortality Adverse events including TE events | Transfusion requirements^††^ Blood loss Operating time Hospital LOS

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

U Median;

†† Examples of transfusion requirements are red blood cells and fresh frozen plasma;

OLT=orthotopic liver transplantation; SD=standard deviation; Rx=treatment group(s); Ucare=usual care; TE=thromboembolic; RBCs=red blood cells; FFP=fresh frozen plasma; INR=international normalized ratio; NSAID=non-steroidal anti-inflammatary drugs; LOS=length of stay

Place of studies within analytic framework. Liver transplantation is the one indication for which all of the included studies evaluated rFVIIa for prophylactic use (versus treatment or end-stage use, which are other potential uses, as outlined in our Analytic Framework (Figure 1)). Among the four RCTs, those by Lodge,110 Planinsic,111 and Pugliese 112 reported at least minimal comparative data on the direct outcomes of mortality and thromboembolic events and the indirect outcomes of RBC transfusion requirements, operating room (OR) time, and ICU length of stay, wheres the Liu RCT113 only reported comparative data on OR time. Furthermore, only the Lodge and Planinsic studies explicitly identified a “primary outcome” (in this case, two for both)—RBC transfusion requirements during the procedure itself and during the first 24 hours post-peratively. The Hendriks observational study did not identify a primary outcome, but reported on the direct endpoints of thromboembolic events and the surrogate endpoints of transfusion requirements, blood loss, and operating time.

Comparison to studies on other indications. The studies of rFVIIa use in liver transplantation all evaluated its prophylactic application in comparison to the treatment use to which it was applied in most of the other indications. The mean age of patients was approximately 50 years, which is similar to those in the studies of brain trauma and younger than those in the studies of intracranial hemorrhage or adult cardiac surgery. The dose of rFVIIa was broad, with an approximate range of 20–360 μg/kg. All but one study evaluated a single dose of rFVIIa.

### Patient Characteristics and Study Design

None of the studies described having enrolled patients who were Jehovah’s Witnesses.

RCTs. We identified four RCTs (two fair quality, two poor quality (Table 14)). The first, by Lodge,110 was a double -blind study with modest sample sizes: 61 patients in the usual care group and 121 patients in the aggregate rFVIIa group (divided relatively evenly between two dosing groups). It was conducted in 14 hospitals in Europe between August 2001 and September 2003. Inclusion criteria targeted adults with end-stage liver disease (defined as Child-Pugh class B or C) requiring liver transplantation. Important exclusion criteria included previous liver transplantation and multiorgan transplantation, both of which are associated with higher rates of bleeding during surgery. The groups were well-matched at baseline, with the possible exception of the rFVIIa patients having a slightly higher rate of B scores on the Child -Pugh scale (i.e., they may have been slightly less sick) than the usual care group.

The Planinsic RCT111 was a double -blind study with small sample sizes: 19 patients in the usual care group and 64 patients in the aggregate rFVIIa group (divided relatively evenly between three dosing groups). It was conducted in nine hospitals in the U.S. and Europe between February and September 2000. The inclusion and exclusion criteria, baseline matching, and primary outcomes were essentially the same as those described for the Lodge RCT above.

The primary outcomes reported were the number of RBC units transfused both intraoperatively and in the first post-operative 24 hours.

The Pugliese RCT112 was a double -blind study with very small sample sizes: 10 patients in the usual care group and 10 in the rFVIIa group. It was conducted at a single Italian center from November 2003 to July 2004, and had an extremely short six hour time frame of data collection and follow-up. Inclusion criteria included patients “who underwent OLT [orthotopic liver transplantation]” (Child-Pugh class not specified) and who also had hemoglobin greater than eight mg/dL, INR greater than 1.5, and fibrinogen greater than 100 mg/dL. Exclusion criteria and the primary outcome were not specified.

The Liu RCT113 contained no description of blinding and was also small, with 14 patients in both the treatment and usual care groups. It was conducted at a single center in China from March 2003 to July 2006 and does not designate the timeframe of follow-up. The sole inclusion criterion appears to have been need for liver transplantation, and the exclusion criteria and primary outcome were not specified.

Comparative observational study. The fair quality Hendriks cohort study evaluated patients treated at a single hospital in the Netherlands.114 It evaluated only 12 patients who received usual care matched in a 2:1 ratio with six patients who received rFVIIa. Inclusion criteria were similar to those of the Lodge and Planinsic RCTs, namely adult patients with end-stage liver disease (defined as Child-Pugh class B or C) requiring liver transplantation. Controls were chosen from the hospital database of patients who had received a liver transplantation. They were matched in a 2-to-1 ratio with rFVIIa patients on the characteristics of year of transplantation, Child-Pugh score, blood urea nitrogen levels, and cholestatic versus non-cholestatic liver disease. The groups were well matched at baseline, with the possible exception of longer cold ischemia time for the livers transplanted into the usual care group. The primary outcome was not specified.

### Intervention Characteristics

RCTs. Patients in the four RCTs received infusions of rFVIIa or placebo at the initiation of surgery. In the Lodge study,110 treated patients received one dose of either 60 or 120 μg/kg at the initiation of surgery, repeat doses in the same amount every two hours while still in the OR, and a final dose in the same amount at the time of wound closure. Most patients in the study received a total of three doses for approximate cumulative doses of 120 and 360 μg/kg, respectively. In the remainder of the studies, treated patients received a single dose of rFVIIa: in the Planinsic study111 a dose of 20, 40, or 80 μg/kg; in the Pugliese study112 a dose of 40 μg/kg; and in the Liu study113 a dose of “70–80 μg/kg.”

Comparative observational study. Treated patients in the Hendriks cohort study 114 received a single 80 μg/kg dose of rFVIIa at initiation of surgery.

### Outcomes

Direct (patient-centered) outcomes. There were no dose -dependent trends in the outcomes reported and the events rates for these outcomes were low. Therefore, the event rates in the text are given for the aggregate rFVIIa group compared to the usual care group. Table 35 also summarizes these findings.

Table 35 Mortality and thromboembolic events in comparative studies of rFVIIa use in liver transplantation

Article | Study Design and rFVIIa use | Mean dose (SD) [Range] | Sample size | | Mean age (SD) [Range] | | Mortality rate | | | Thromboembolic event rate&
| | | rFVIIa | Usual care | rFVIIa | Usual care | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig
Lodge 2005^110^ | RCT Prophylaxis | 180^#^ 360^#^ | 63 58 | 62 | 53.3 (11.2) 52.6 (9.2) | 52.3 (11.5) | 0.016* 0.034* | 0.016* | NR | 0.190^ 0.121^ | 0.097^ | NS
Planinsic 2005^111^ | RCT Prophylaxis | 20 40 80 | 18 24 22 | 19 | 49.4 (13.4) 49.7 (10.1) 51.9 (8.8) | 49.9 (11) | 0.056* 0.083* 0.045* | 0.053* | NR | 0.222 0.083 0.091 | 0.158 | NR
Pugliese 2007^112^ | RCT Prophylaxis | 40 | 10 | 10 | NR | NR | 0 | 0 | NR | 0 | 0 | NR
Liu 2009^113^ | RCT Prophylaxis | [70–80] | 14 | 14 | 51.9 [36–54] | 47.5 [41–65] | NR | NR | NR | 0 | NR | NR
Hendriks 2001^114^ | Cohort Prophylaxis | 80 | 6 | 12 | 43^U^ [37–61] | 48^U^ [34–63] | NR | NR | NR | 0.167 | 0 | NR
De Gasperi 2005^115,†^ | Retrospective comparative Prophylaxis | [20–40] | 6 | 6 | 45 (4) | 47 (9) | 0 | 0 | NR | NR | NR | NR
Kalicinski 2005^116,†^ | Retrospective comparative Prophylaxis | 52 [30–100] | 28 | 61 | 13 (4) | 11 (6) | 0.071 | 0.082 | NR | 0 | 0.098 | NR
Neimann 2006^117,†^ | Retrospective comparative Prophylaxis | 58 (18) | 11 | 11 | 48 (15) | 41 (17) | 0 | 0.09 | NR | 0 | 0.09 | NR

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies.

& Thromboembolic event rates were calculated by dividing the number of thromboembolic events by the sample size, not the number of patients who experienced thromboembolic events. Therefore, the rates reported here may differ slightly from those reported in each study. The tests of statistical significance presented are those reported by the individual studies and are not based upon the thromboembolic event rates reported in this table.

* Mortality rate is underestimated in Lodge 2005^110^ and Planinsic 2005^111^ because in each study two additional deaths were not reported by trial arm.

^ Lodge 2005^110^ reports arterial thromboembolic events only.

# The majority of patients in Lodge 2005 110 received 3 doses of either 60 or 120 ug/kg rFVIIa (range: 3–6 dose).

NR=not reported; NS=not significant

U Median

[underlined: Mortality.] The Liu RCT 113 did not report on mortality. The remaining three RCTs failed to define explicitly the time to follow-up for the mortality endpoint. However, all of them reported on the number of transfusions within the first 24 -hour post-operative period and/or the subsequent ICU length of stay, such that the minimum follow-up time for mortality may reasonably be expected to be 24 hours. There were no differences between groups in mortality rates, although the studies were not powered for this outcome. The Lodge study110 noted “6 deaths” in the text but provided further details on only four of these in its associated table, for minimum mortality rates of two percent (3 of 121) in the aggregate rFVIIa group and two percent (1 of 61) in the usual care group. The Planinsic study111 stated that “seven deaths occurred during the study period,” but described only five deaths for the following minimum mortality rates: six percent (4 of 64) in the aggregate rFVIIa group and five percent (1 of 19) in the placebo group. The Pugliese study112 reported no deaths in either group. The Hendriks cohort study114 also did not report on mortality. To place the mortality differences in the context of the comparable findings for the other clinical indications, also see Figure 5 above (in the Key Question section on intracranial hemorrhage).

[underlined: Thromboembolic events.] There were no differences between groups noted by any of the studies for this outcome. The Lodge RCT110 noted 16 percent (19 of 121) in the aggregate rFVIIa group and 10 percent (6 of 61) in the usual care group. The Planinsic RCT111 described thromboembolic event rates of 13 percent (8 of 64, comprised of five arterial thromboses, one myocardial infarction, and two episodes of thrombophlebitis) in the aggregate rFVIIa group and 16 percent (3 of 19, comprised of two arterial thromboses and one episode of thrombophlebitis) in the usual care group. The Pugliese112 RCT stated that no thromboembolic events occurred in either group. The Liu RCT113 only stated that no events occurred in the treatment group, without commenting on the control group. The Hendriks cohort study114 reported only one thromboembolic event in the study—thrombosis of the hepatic artery in a patient who received rFVIIa: an event rate of 17 percent (1 of 6), versus 0 of 12 in the usual care group. To place the differences in thromboembolic event rates in the context of the comparable findings for the other clinical indications, also see Figure 6 above (in the Key Question section on intracranial hemorrhage).

Indirect (surrogate) outcomes. There were no dose-dependent trends noted for the indirect outcomes described in detail below and summarized in Table 36.

Table 36 Indirect outcomes in comparative studies of rFVIIa use in liver transplantation

Article | Study Design/rFVIIa use | Mean dose (SD) [Range] | Sample size | | Mean age (SD) [IQR] | | Mean RBC transfusion (SD) [IQR] | | | OR time, minutes (SD) | | | ICU LOS, days (SD)
| | | rFVIIa | UC | rFVIIa | Usual care | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig
Lodge 2005^110^ | RCT Prophylaxis | 180^#^ 360^#^ | 62^*^ 56^*^ | 61 | 53.3 (11.2) 52.6 (9.2) | 52.3 (11.5) | 7.0^U^ [0–76.5]^R^ 6.3^U^ [0–76.4]^R^ | 8.2^U^ [1.5–100.0]^R^ | NS | “same” | “same” | NS | 3.5 3.0 | 3.0 | NS
Planinsic 2005^111^ | RCT Prophylaxis | 20 40 80 | 18 23 22 | 19 | 49.4 (13.4) 49.7 (10.1) 51.9 (8.8) | 49.9 (11.0) | 10.0^U^ [3.0–18.0] 13.0^U^ [7.0–24.0] 10.0^U^ [3.2–21.0] | 11.1^U^ [7.0–17.0] | NS | “same” | “same” | NS | “same” | “same” | NS
Pugliese 2007^112^ | RCT Prophylaxis | 40 | 10 | 10 | - | - | 1.2 (0.53) | 2.3 (0.44) | p=.02 | 408 (56) | 432 (48) | NS | 4.8 (1.3) | 5.2 (1.2) | NS
Liu 2009^113^ | RCT Prophylaxis | [70–80] | 14 | 14 | 51.9 [36–54] | 47.5 [41–65] | ** | ** | ** | 268 (42) | 485 (65) | p<.01 | NR | NR | NR
Hendriks 2001^114^ | Cohort Prophylaxis | 80 | 6 | 12 | 43^U^ [37–61]^R^ | 48^U^ [34–63]^R^ | 3.0^U^ [0–5]^R^ | 9.0^U^ [4–40]^R^ | p=.002 | 554 | 598 | p=.26 | NR | NR | NR
De Gasperi 2005^115,†^ | Retrospective comparative Prophylaxis | [20–40] | 6 | 6 | 45 (4) | 47 (9) | 9 (4) | 7 (2.5) | NS | NR | NR | NR | NR | NR | NR
Kalicinski 2005^116,†^ | Retrospective comparative Prophylaxis | 52 [30–100] | 28 | 61 | 13 (4) | 11 (6) | ^ | ^ | ^ | 522 (110) | 534 (118) | p=.35 | 7.03 (5.94) | 6.15 (5.55) | p=.32
Neimann 2006^117,†^ | Retrospective comparative Prophylaxis | 58 (18) | 11 | 11 | 48 (15) | 41 (17) | 3.9 (2.6) | 6.9 (2.3) | p=.01 | 416 (104) | 430 (84) | p=.7 | ## | ## | ##

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies.

# The majority of patients in Lodge 2005^110^ received 3 doses of either 60 or 120 ug/kg rFVIIa (range: 3–6 doses);

* 1 patient in the 180 ug/kg group and 2 patients in the 360 ug/kg group were excluded from the analysis;

** Liu 2009^113^ does not report on RBC transfusion but does report blood loss: rFVIIa 2250 mL (SD 350), placebo 6214 mL (SD 750), p<0.01;

^ Total intraoperative blood transfusion volume (not isolated to RBCs): rFVIIa, 1980 mL; usual care, 1527 mL (NS);

## Total hospital length of stay (not isolated to ICU length of stay): rFVIIa, 11 (SD 7.3) days; 7.9 (SD 2.7) days (p=0.2);

R Denotes range instead of IQR;

U Median; NR=not reported; NS=not significant; UC=usual care; “same” means that both studies stated, “No notable differences between study groups were found with respect to … operation duration,” (Lodge 2005^110^ and Planinsic 2005^111^) or that “The mean number of intensive care units days was comparable between studies.” (Lodge 2005^110^).

[underlined: RBC transfusion during the 24-hour post-operative period.] Among the RCTs, the Lodge study identified a non-significant reduction and the Pugliese study identified a significant reduction in the 24-hour post-operative RBC transfusion requirements with treatment, whereas the Planinsic study found no difference between groups. The Liu study did not report this outcome, but did note a significant reduction in blood loss. In the Hendriks cohort study114 the treatment group had significantly lower RBC transfusion requirements.

[underlined: OR time.] Only the Liu RCT identified a significant difference between groups in OR time, with transplantation taking over 200 minutes less in the rFVIIa group compared to placebo. None of the other studies identified a difference between groups. Both the Lodge110 and Planinsic111 RCTs reported “no notable difference between study groups” for this outcome but gave no further details. While the OR times were slightly shorter for the rFVIIa patients compared to controls in both the Pugliese RCT and Hendriks cohort study (in minutes, 408 versus 432 and 554 versus 598, respectively), these differences were not significant.

[underlined: ICU length of stay (LOS).] None of the RCTs reporting on this outcome found a difference between groups in ICU LOS. The Planinsic RCT111 stated only that “the mean number of intensive care unit days was comparable between study groups,” whereas the Lodge and Pugliese RCTs did report duration for each group. The Liu RCT and Hendriks cohort did not report on this outcome.

Consideration of poor quality comparative observational studies. In the poor quality comparative observational studies by De Gasperi,115 Kalicinski, 116 and Niemann, 117 the findings on mortality, thromboembolic events, and RBC transfusions requirements were consistent with those described above (Tables 35 and 36). Other outcomes were not reported.

### Comparison to Premier Database

The mean age of study patients of approximately 50 years was comparable to the mean age of 52 years for Premier patients. Mortality rates among patients in all of the comparative studies were considerably lower than the mortality rate of 0.38 for patients who underwent liver transplantation in the Premier database.

### Strength of Evidence

The strength of evidence assigned to all outcomes was low (Table 37). These assessments were made, in part, on the basis of the poor to fair quality scores of the included studies, which prompted a determination that the studies had a medium or high risk of bias in all cases. In addition, there was little certainty regarding the effect size estimates, leading to uniform imprecision on that determinant. Low event rates for all of the morbidity and mortality outcomes contributed to the imprecision for these outcomes, while wide confidence intervals contributed to the imprecision for the surrogate outcomes.

Table 37 Strength of evidence grade for rFVIIa use in liver transplantation

Outcome of Interest | Number of Studies | Number of Subjects | | Domains Pertaining to Strength of Evidence | | | | | | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Domains Pertaining to Risk of Bias | | | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Design | Quality | Overall Risk | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Mortality (timeframe unclear) | 3^110–112^ | 195 | 90 | RCT | Fair | Medium | Consistent | Direct | Imprecise | No Effect | No | Low
Mortality (timeframe unclear) | 1^114^ | 6 | 12 | COBS | Fair | High | Unknown | Direct | Imprecise | No Effect | Unknown | Low
Thromboembolic Events | 3^110–112^ | 195 | 90 | RCT | Fair | Medium | Consistent | Direct | Imprecise | No Effect | No | Low
Thromboembolic Events | 1^114^ | 6 | 12 | COBS | Fair | High | Unknown | Direct | Imprecise | No Effect | Unknown | Low
Units of RBCs Transfused in 24 hours | 3^110–112^ | 195 | 90 | RCT | Fair | Medium | Consistent | Indirect | Imprecise | Weakly Favors rFVIIa | No | Low
Units of RBCs Transfused in 24 hours | 1^114^ | 6 | 12 | COBS | Fair | High | Unknown | Indirect | Imprecise | Weakly Favors rFVIIa | Unknown | Low
OR Time | 1^112, 113^ | 24 | 24 | RCT | Poor | High | Inconsistent | Indirect | Imprecise | No Effect | Unknown | Low
OR Time | 1^114^ | 6 | 12 | COBS | Fair | High | Unknown | Indirect | Imprecise | No Effect | Unknown | Low
ICU Length of Stay | 3^110–112^ | 195 | 90 | RCT | Fair | Medium | Consistent | Indirect | Imprecise | No Effect | No | Low

RCT= randomized controlled trial; ICU=intensive care unit; COBS=comparative observational study; RBCs=red blood cells; OR=operating room. See Tables 4 to 7 for definitions of study quality and strength of evidence domains and designations.

### Applicability

The overall applicability was fair for prophylactic use in the population targeted—adult patients with cirrhosis of Child’s class B or C. Such patients represent the usual population requiring liver transplantation for cirrhosis. The range of rFVIIa doses administered limits applicability in terms of choice of prophylactic dose. Another limitation is the emphasis on indirect (surrogate and process) outcomes, rather than direct measures of mortality and morbidity, which would have required much larger studies. Follow-up times were short and poorly defined, and in most cases there were limited descriptions of ascertainment for harms, which reduces study applicability in these areas. Finally, the setting of the studies in regional referral centers in the U.S. and abroad has good applicability to U.S. centers where liver transplantations are performed (Table 38). The evidence is not applicable to treatment or end -stage use of rFVIIa for this indication or to patients who require liver transplantation for indications other than Child’s B or C cirrhosis, because such patients were excluded.

Table 38 Applicability assessment of studies on liver transplantation

Describe Available Evidence | Describe Overall Implications for Applicability
Population
Patients undergoing orthotopic liver transplantation with Child’s class B or C cirrhosis Mean age 50 Patients with abnormal clotting systems secondary to liver disease There is no mention of Jehovah’s witness patients within the study populations Exclusions: Patients who require transplantation for indications other than Child’s class B or C cirrhosis and/or who are on anticoagulation | rFVIIa use for this indication is very rare in U.S. but nonetheless the study findings are likely applicable to many of those undergoing liver transplantation, and may be relevant to select subgroups such as Jehovah’s witness patients, although such patients do not appear to have participated in the studies Other approaches available to minimize blood loss
Intervention
Prophylactic use of rFVIIa, either as a single dose of 20 to 80 mcg/kg prior to surgery, or as repeating doses for an aggregate dose of 213 or 412 mcg/kg. Usual care, including transfusion protocol | Dose is variable, with high dose studies higher than for other prophylactic uses
Comparator
Usual care via randomization or matched controls | Other prophylactic hemostatic agents potential comparators, but not used in this setting
Outcomes
Primary outcomes: Red blood cell transfusions over 24h and perioperative blood loss Secondary outcomes: length of stay, operative time, thromboembolic events, coagulation lab parameters | Surrogate/indirect outcomes related to process of care without direct link to clinical outcomes Insufficient sample size to meaningfully assess clinical outcomes Quality of life or functional outcomes are absent
Timing and intensity of follow-up
Follow-up for duration of hospitalization Seldom had protocol for ascertainment of harms | Longer term outcomes and a protocol for ascertainment of harms is desirable
Setting
Academic hospitals in the U.S. and Western Europe that serve as regional referral centers | Highly applicable to U.S. transplantation centers

### Conclusions

The available evidence of low strength is too limited to compare the benefits and harms of prophylactic use of rFVIIa compared to usual care in liver transplantation. There was no evidence of impact on mortality or thromboembolic events but event rates were low. There was a weak trend toward reduced RBC transfusion requirements in the studies as a whole, but no differences between groups for the other indirect outcomes (OR time and ICU length of stay). Study patients were comparable in age to those in the Premier database but had lower mortality rates. The impact of rFVIIa on the care of Jehovah’s Witness patients remains unclear, in the absence of comparative study data in this population.

## Key Question 4.b.i. Adult cardiac surgery and comparative effectiveness of rFVIIa

### Background

Despite advances in methods to control blood loss during and after cardiac surgery, perioperative blood transfusions are required in up to 80 percent of adult patients, and 3–5 percent of these patients require post-operative transfusions of over 10 RBC units. 202–204 Mediastinal exploration for ongoing post-operative bleeding is necessary in 3–10 percent of patients.205,206 Post-operative bleeding that is refractory to surgical re-exploration or conventional hemostatic therapy is felt to be multifactorial, with contributions from the use of antiplatelet agents prior to surgery and various causes of coagulopathy triggered by the surgery itself: residual heparin effect after cardiopulmonary bypass (CPB), hypothermia, hemodilution causing both thrombocytopenia and dilutional coagulopathy, consumption of coagulation factors, hyperfibrinolysis, inflammatory cascade activation, and platelet consumption and dysfunction.207,208

Because anticoagulation is necessary during the period on CPB, the optimal time period for potential use of rFVIIa is some time after discontinuation of CPB and reversal of the anticoagulation. For “prophylaxis” of post-CPB bleeding, rFVIIa is administered immediately after conclusion of CPB. For “treatment” of post-CPB bleeding, rFVIIa is given at such time (variably defined) when excessive bleeding is identified and felt to require treatment. One group of patients known to be at increased risk for excessive bleeding includes those who have undergone complex cardiac surgeries: repeat surgeries, surgeries involving more than one procedure (e.g., multiple valve replacements or repairs), aortic root or arch replacements, and surgeries for aortic dissection or endocarditis.202

Usual care during the time frame of included studies. Ten years ago, 25–95 percent of adult cardiac surgery patients in the U.S. and U.K. received at least one unit of RBCs post-operatively, with wide variations in local practice. But recent studies have exposed the potential detrimental effects of post-operative transfusion.209 Murphy and Angelini evaluated studies published from 1996 to 2006 and found consistent evidence that transfusions increased the likelihood of infection, stroke, renal failure, prolonged ventilation, and both short-and long-term mortality.210 Thus, usual care appears to be shifting toward limiting the practice of post-operative transfusion, whenever possible. All of the included studies were completed by November 2007, when the antifibrinolytic drug aprotinin—commonly used during cardiac surgeries until that time—was removed from the U.S. market due to safety concerns. Since then, tranexamic acid has become the antifibrinolytic agent of choice during cardiac procedures.

### General Characteristics of Studies of Adult Cardiac Surgery

We identified for inclusion two RCTs (one good quality, one fair quality) and four comparative observational studies (two good quality, two fair quality) with 252 patients given rFVIIa as prophylaxis or treatment use following completion of CPB. One RCT examined the efficacy of rFVIIa as prophylaxis for bleeding and given immediately after termination of CPB in complex, non-coronary artery bypass grafting (non-CABG) surgery (Table 39). It stated that it was not sponsored by Novo Nordisk.118 A second RCT evaluated rFVIIa use following any cardiac surgery requiring CPB, including isolated CABG, as treatment for excessive post-operative bleeding in the ICU, similar to the comparative observational studies described below. This latter study was sponsored by the manufacturer. A third RCT, Ma 2006, 211 was published in Chinese but contained an abstract and data tables in English. It examined prophylactic administration of rFVIIa immediately following CPB. It is not included in our primary analyses but is used for sensitivity analyses.

Table 39 General characteristics of comparative studies on off-label rFVIIa use for adult cardiac surgery

Article | Study Design | Study Setting and Time Period | Sample Size and Dose (μg/kg) | Population Characteristics | | Outcomes Evaluated
| | | | Mean Age (SD) [Range] | Inclusion/Exclusion Criteria | Direct | Indirect
Diprose 2005^118^ | RCT Prophylaxis | 1 Center Southampton, UK Time period not reported. | All Rx: 10 Ucare: 10 Dose: 90 ug/kg | Rx: 69.5^U^ [63.5–76.5]^I^ Ucare: 63^U^ [59–66]^I^ | Inclusion: -scheduled to undergo complex non-coronary cardiac surgery requiring CPB. -over 18 Exclusion: -recent thrombotic disease | Mortality TE events (stroke and MI only) | Transfusion requirements^††^ Blood loss Hospital and ICU LOS
Gill 2009^119^ | RCT Treatment | 30 Centers 13 countries 8/2004–11/2007 | All Rx: 104 40: 35 80: 69 Ucare: 68 | Rx: 40: 68 (12) 80: 63 (16) Ucare: 62 (16) | Inclusion: -completed cardiac surgery requiring CPB and had been admitted to postoperative care environment for at least 30 minutes and who were bleeding at a prespecified rate based on blood volume from mediastinal drains. Exclusion: -required urgent re-operation -history of stroke or other non-coronary thrombotic disorder -procedure involving transplantation or implantable ventricular assist device -congenital clotting or bleeding disorder | Mortality Adverse events including TE events | Transfusion requirements^††^ Blood loss
Karkouti 2005^120^ | Retrospective comparative Treatment | 1 Center Toronto, Canada 11/2002–2/2004 | All Rx: 51 Ucare: 51 Mean Dose: 62 ug/kg SD: 13 ug/kg | Rx: 56 Ucare: 59 | Inclusion: -massive blood loss (blood loss>2000 mL or required transfusion of at least 4 units RBCs precluding □terna closure, or blood loss>100 mL/hr in the ICU). -refractory blood loss (e.g. surgical source of bleeding excluded, antifibrinolytics administered, transfusion protocol completed, coagulation measures corrected to within 50% of normal) SAS Greedy 5 1 method was used to match one control patient to each study patient according to propensity score. | Mortality Adverse events including TE events | Blood loss Hospital and ICU LOS
Von Heymann 2005^123^ | Retrospective comparative Treatment | 1 Center Study location not reported. 6/2000–3/2003 | All Rx: 24 Ucare: 24 Dose: 60–80 ug/kg with possible second and third doses if blood loss continued at >100 mL/hr. | Rx: 65 Ucare: 65 | Inclusion: All patients receiving rFVIIa for cardiac surgery. rFVIIa could be administered “if despite adequate conventional hemostatic therapy, excessive bleeding continued.” Controls: Historical controls (1998–2002) with blood loss during first 14 hours>1000 mL, matched on baseline and perioperative characteristics (e.g. single procedure versus combined procedure, implantation of ventricular assist device, need for emergency surgery) | Mortality Adverse events including TE events | Transfusion requirements^††^ Blood loss ICU LOS Need for surgical re-exploration
Tritapepe 2007^122^ | Retrospective comparative Treatment | 1 Center Rome, Italy 1/2000–3/2006 | All Rx: 23 Ucare: 23 Mean dose: 82 ug/kg | Rx: 62.4 (9.4) Ucare: 62.2 (9.1) | Inclusion: -Aortic dissection surgery -“life-threatening” postcardiac surgery hemorrhage (i.e. blood loss > 150 mL/hr) -surgical source of bleeding excluded by >2 hours of surgical exploration Controls: SAS Greedy 5 1 method was used to match one control patient to each study patient according to propensity score. | Mortality Adverse events including TE events | Transfusion requirements^††^ Blood loss ICU LOS
Gelsomino 2008^121^ | Retrospective comparative Treatment | 1 Center Florence, Italy 9/2005–6/2007 | All Rx: 40 Ucare: 40 Median Dose: 18.3 ug/kg, IQR: 9–16 ug/kg | Rx: 70.1 (9.2) Ucare: 75.8 (9.8) | Inclusion: -significant bleeding (i.e. >500 mL/hr during first postoperative hour, >300 mL/hr for three consecutive hours after chest closure, or >1200 mL/hr after fifth postoperative hour) -refractory blood loss (e.g. surgical source of bleeding excluded, antifibrinolytics administered, transfusion protocol completed, coagulation measures corrected to within 50% of normal) Controls: SAS Greedy 5 1 method was used to match one control patient to each study patient according to propensity score. | Mortality Adverse events including TE events | Transfusion requirements^††^ Blood loss ICU LOS Need for surgical re-exploration
Bowman 2008^124,†^ | Retrospective comparative Treatment | 1 Center South Carolina, USA 1/2001–12/2006 | All Rx: 36 Ucare: 385 Mean dose: 100 ug/kg | Rx: 58 (15) Ucare: NR | Inclusion: -adults undergoing “high-risk” cardiac surgeries (transplantation, aortic surgery, redo operations, or multiple cardiac procedures in one operation) -exclusion of surgical bleeding, failure to reverse coagulopathy with standard means, correction of core body temperature to normal, adequate heparin reversal, and (for those in the ICU) chest tube output of at least 3 mL/kg/h for at least 2h Controls: contemporaneous cohort of adults undergoing “high-risk” cardiac surgeries. | Mortality Adverse events including TE events | Transfusion requirements^††^ (rFVIIa pts only)
Trowbridge 2008^125,†^ | Prospective comparative | 1 Center Pennsylvania, USA Time period not reported. | All Rx: 17 Ucare: 187 Mean dose not reported. | Rx: 69.6 (8.9) Ucare: 66.5 (11.3) | Inclusion: -adult cardiac surgery patients with “uncontrolled hemorrhage” (e.g., non-surgical bleeding, platelet count>100), thereby meeting institutional guidelines for “rescue therapy” with rFVIIa Controls: contemporaneous cohort of adult cardiac surgery patients without “uncontrolled hemorrhage” | None reported | Transfusion requirements^††^

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

U Median;

I Interquartile range;

†† Examples of transfusion requirements are red blood cells and fresh frozen plasma

IQR=interquartile range; SD=standard deviation; Rx=treatment group(s); Ucare=usual care; NR=not reported; TE=thromboembolic; INR=international normalized ratio; LOS=length of stay

The remainder of the studies, one prospective cohort212 and four retrospective cohorts, 120–123 also evaluated rFVIIa used as treatment for excessive post-operative bleeding, typically in patients with non-CABG surgery. A certain number of patients receiving isolated CABG were included in some of the studies,121,123 most notably in the Gelsomino cohort, of which approximately 45 percent received an isolated CAGB.121 The definition of “excessive bleeding” across studies was variable, but generally included some combination of the following criteria: bleeding that compromised hemodynamics, prevented chest closure, or crossed a certain threshold in the first post-operative hour (range 100–500 mL/h) or for a certain number of consecutive hours thereafter (range 100–300 mL/h). The majority of the patients in each study, and in some cases all of them, received the study drug in the ICU. One of these studies made no mention of manufacturer sponsorship, 121 while the other three explicitly stated that they had no such sponsorship.120,122,123

Place of studies within analytic framework. Adult cardiac surgery was the only indication for which there were comparative studies on more than one type of use of rFVIIa, namely prophylactic and treatment dosing (but not end-stage use) (see our Analytic Framework (Figure 1)). The Diprose RCT118 examined prophylactic use, while the Gill RCT119 examined treatment use, although in both cases, rFVIIa was given after termination of CPB. The remaining four studies, 120–123 all of which were observational, examined treatment use. All of the studies provided comparative data of some sort on the direct outcomes of mortality and thromboembolic events and the surrogate outcomes of RBC (or in the case of the Gill RCT, total) transfusion requirements, as well as ICU length of stay.

Qualitative considerations of heterogeneity. One obvious source of potential heterogeneity among the adult cardiac surgery studies is the distinction between prophylactic and treatment use. However, in both types of use, rFVIIa is administered after CPB has concluded, when the effects of the many potential causes of coagulopathy discussed above may already be in full force—including the effects of residual heparin from CPB, hypothermia, hemodilution, platelet consumption and dysfunction, and the like. For this reason, we determined that patients in the one study on prophylactic rFVIIa use, the Diprose RCT, might be expected to respond to the drug similarly to the patients in the remaining studies of treatment use, and we therefore chose to analyze the studies together.

Comparison to studies on other indications. Like the Diprose RCT (and the Ma RCT in Chinese used for sensitivity analyses), the other indications that assessed prophylactic use of rFVIIa are those of liver transplantation, pediatric cardiac surgery, and prostatectomy. In contrast, the Gill RCT and all of the cohort studies evaluated treatment use of rFVIIa for bleeding during or after surgery, similar to the ICH and trauma indications. The mean age in the studies ranged from the mid to high 60s, which is comparable to the mean ages in the intracranial hemorrhage and prostatectomy studies. The rFVIIa dose was on the lower end of those studied (17–90 μg/kg) and was typically only given in the form of 1–2 infusions, rather than the multiple infusions seen in some of the other indications.

### Patient Characteristics and Study Design

RCTs. The fair quality Diprose RCT 118 was a small double blind study of prophylactic use of rFVIIa conducted in one U.K. hospital with 10 patients in the usual care group and 10 patients in the rFVIIa group, and with the administration of the study drug or placebo at the conclusion of CPB. To qualify for inclusion, patients had to have undergone complex cardiac surgery, defined as repeat non-coronary surgery, multiple valve surgeries, surgery at the aortic root or arch or for aortic dissection, or surgery for endocarditis. All patients in the study received a set dose of aprotinin during surgery. While the study identified no single primary outcome, it reported on various transfusion requirements for the intention-to-treat population. However, the outcomes of mortality, thromboembolic events, and ICU length of stay were reported only for the per-protocol population, which excluded one patient from the rFVIIa group for incurring “multiple transfusion protocol violations” after being unblinded at the request of the surgeon.

The good quality Gill RCT119 evaluated treatment use of rFVIIa for excessive post-operative bleeding in the ICU, was conducted in the U.S. and 12 other countries (in Africa, Asia, Europe, and South America), and enrolled 172 patients total, including 68 patients in the usual care group and 104 patients in the rFVIIa group. The description on the ClinicalTrials.gov website indicates that the trial was terminated in November 2007 “without proceeding to the highest dosing cohort [of 160 μk/kg] as this no longer reflects common clinical practice.”213 To qualify for inclusion, patients had to have undergone cardiac surgery that required CPB, which could include simple CABG (12 to 14 percent of patients in each group received only CABG), and also have reached a prespecified bleeding rate (>200 mL/h or >2 mL/kg/h for 2 consecutive hours) after a 30 minute stabilization period in the ICU. Patients were excluded if they were determined to require urgent re-operation or had a history of stroke or non-coronary thrombotic disorder. In the publication there is no mention of whether patients received aprotinin or tranexamic acid for antifibrinolysis during surgery. The primary outcome was the incidence of critical serious adverse events at 30 days, which could include death, myocardial infarction (MI), stroke, pulmonary embolus (PE), or other symptomatic thromboembolic events. Other outcomes reported in the publication included total transfusion volume and blood loss, but not ICU length of stay.

The Ma RCT211 published in Chinese and used for sensitivity analyses evaluated prophylactic rFVIIa use immediately following conclusion of CPB in 11 usual care patients versus 11 treatment patients. All patients underwent valve repair surgery, with a sub-set undergoing a double valve repair (27 percent rFVII group, 36 percent placebo); there were no other types of surgery performed. Because we have limited access to methodological information and outcomes data—based only on the English-language abstract and results tables—we used the data for sensitivity analyses but did not include them in the primary analyses.

Comparative observational studies. We identified four comparative observational studies (two good quality, two fair quality (Table 14)). Again, all of these studies assessed the treatment use of rFVIIa compared to usual care for ongoing bleeding after discontinuation of CPB. The two highest quality comparative observational studies were the Karkouti and Gelsomino cohorts, both of which earned “good” scores and were subsequently included with the Diprose and RCTs in the meta-analyses of direct outcomes.

The Karkouti cohort study assessed the first 51 patients treated with rFVIIa for cardiac surgery bleeding at a single Canadian institution between November 2002 and February 2004.^120^ The institutional policy required that a consultant hematologist approve the release of rFVIIa and that bleeding be “massive and refractory,” as defined in the paper. The attending physician could then choose between two doses of rFVIIa which were based on drug vial contents rather than patient weight: a 4.8 mg vial (an approximate 70 μg/kg bolus) or a 2.4 mg vial (an approximate 35 μg/kg bolus). Data were abstracted by a blinded research nurse and research assistant. Each patient who received rFVIIa was matched to a single control selected from the hospital’s database of patients who had undergone cardiac surgery in a similar time frame and using a propensity score that modeled for massive perioperative blood loss. Patients were well matched at baseline on most characteristics, such as complex surgery and mean CPB time, but did have significant differences on baseline rates of re-exploration, blood loss, and transfusion products, all of which were higher in the rFVIIa group. No single primary outcome was identified, but the study reported on outcomes of RBC transfusion requirements, mortality, stroke, MI, PE, deep vein thrombosis (DVT), and ICU LOS, amongst others.

The Gelsomino cohort study121 assessed 40 patients treated at one Italian center, between September 2005 and June 2007, who had all types of cardiac surgeries, including isolated CABG, and received rFVIIa for “significant and refractory bleeding,” as defined in the paper. The dose of rFVIIa was the lowest administered for this indication, consisting of a uniform dose of 1.2 mg (a median dose of 18 μg/kg for included patients) that could be repeated once for continued bleeding. rFVIIa patients were matched 1:1 with 40 controls who received cardiac surgery at the hospital over the same time frame using a propensity score. Patients were well matched at baseline for important characteristics, such as the proportion undergoing complex cardiac surgery (approximately 40 percent in each group) and baseline transfusion requirements. The one possible exception to successful matching was the 30 minute longer CPB time in the usual care group (p=0.06). No single primary outcome was identified, but the study reported on outcomes of RBC transfusion requirements, mortality, stroke, respiratory failure, and ICU LOS, amongst others.

The von Heymann cohort123 identified 26 patients who received 1–3 doses of 60 μg/kg rFVIIa at a median of 14 hours following CPB at one German institution between June 2000 and March 2003. The majority of patients received a single dose. The study subsequently excluded two patients because they died during the initial 24-hours after treatment. The remaining 24 treated patients were matched 1:1 with controls from a similar time frame and the same hospital. The controls had to have experienced blood loss over 1000 mL in the first 14 hours after CPB, and were also matched to rFVIIa patients based on the “complexity” of the surgery (defined as single procedure (e.g., isolated CABG or single valve) or combined procedure (e.g., CABG plus valve replacement)). While groups were well-matched at baseline on APACHE II scores, there were possibly important differences in rates of emergency or redo surgeries (higher in the usual care group) and liver failure and endocarditis (higher in the rFVIIa group). No single primary outcome was identified, but the study reported on outcomes of RBC transfusion requirements, need for reexploration, mortality, thromboembolic events, and ICU LOS, amongst others.

The Tritapepe cohort122 was the only study to report on patients who received a single type of surgery, in this case repair of proximal type A aortic dissections, a high-risk, complex cardiac surgery. It identified 23 consecutive patients who received at least one 70 μg/kg dose of rFVIIa for refractory bleeding between January 2000 and March 2006. The majority of patients received a single dose. Usual care patients were matched 1:1 with rFVIIa patients based on a propensity score for “use of rFVIIa,” the modeling of which did not include a variable for baseline bleeding or transfusion requirements. The groups were otherwise well-matched on baseline characteristics, with the possible exception of higher rates of Bentall procedures in the rFVIIa group. No single primary endpoint was identified, but the study reported on outcomes or RBC transfusion requirements, mortality, stroke, and ICU LOS, among others.

### Intervention Characteristics

RCTs. In the Diprose RCT118 the patients received a single, prophylactic bolus of 90 μg/kg of study drug or placebo immediately following the conclusion of CPB. rFVIIa patients in the Gill RCT119 received one of two possible single doses after a 30-minute stabilization period in the ICU: 35 received 40 μg/kg and 68 received 80 μg/kg. In the Ma RCT211 published in Chinese, which we are using for sensitivity analyses, a single, prophylactic dose of 40 μg/kg was administered immediately after CPB.

Comparative observational studies. In the cohort studies, rFVIIa was administered as treatment for excessive post-CPB bleeding. Compared to the doses used for treatment (rather than prophylaxis) in other clinical indications, these doses were on average much lower: first-time median doses ranged from 18–70 μg/kg, with the majority of patients receiving only a single dose. In the Karkouti cohort,120 attending physicians could choose between two doses of rFVIIa which were based on drug vial content rather than patient weight: a 4.8 mg vial (an approximate 62 μg/kg bolus) or a 2.4 mg vial (an approximate 37 μg/kg bolus). The majority of patients received just one dose. Patients in the Gelsomino cohort121 received the lowest doses of rFVIIa in all of the cohort studies, consisting of a uniform dose of 1.2 mg (which was equal to a median doses of 18 μg/kg) that could be repeated once for continued bleeding—but a repeat dose was required in only three patients. Patients in the von Heymann cohort123 could receive 1–3 doses of 60 μg/kg rFVIIa a median of 14 hours following CPB, but the majority required only a single dose. The Tritapepe cohort122 used an initial treatment dose of 70 μg/kg dose rFVIIa, and, again, the majority of patients received only a single dose.

### Outcomes

Direct (patient-centered) outcomes. Overall, mortality and thromboembolic event rates were consistently reported for the included RCTs and cohort studies. Table 40 summarizes the morbidity and mortality outcomes for the adult cardiac surgery studies. Given the limitations of the data, we were not able to evaluate for a dose-response relationship for these outcomes. As described further below, among the studies included in the meta-analyses, assessments of the significance and magnitude of heterogeneity by the Q and I^2^ statistics did not identify significant heterogeneity.

Table 40 Mortality and thromboembolic events in comparative studies of rFVIIa use in adult cardiac surgery

Article | Study Design and rFVIIa use | Mean rFVIIa dose (SD) [IQR] | Sample size | | Mean age (SD) [IQR] | | Mortality rate | | | Thromboembolic events rate&
| | | rFVIIa | Usual care | rFVIIa | Usual care | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig
Diprose 2005^118^ | RCT Prophylaxis | 90 | 9^ | 10 | 63^U^ [59–66] | 69.5 U [63.5–76.5] | 0 | 0.1 | p=1 | 0.222 | 0.2 | NR
Gill 2009^119^ | RCT Treatment | 40 80 | 35 69 | 68 | 68 (12) 63 (16) | 62 (16) | 0.114 0.087 | 0.059 | NR | 0.086 0.058 | 0.015 | NR
Karkouti 2005^120^ | Retrospective comparative Treatment | 51.1 | 51 | 51 | 56 | 59 | 0.137 | 0.137 | NS | 0.157 | 0.098 | NR
Gelsomino 2008^121^ | Retrospective comparative Treatment | 18 [9–16] | 40 | 40 | 70.1 (9.2) | 73.2 (7.8) | 0.05 | 0.075 | p>0.9 | 0.05 | 0 | NR
von Heymann 2005^123^ | Retrospective comparative Treatment | 89.3 | 24 | 24 | 63.5 | 63.5 | 0.333* | 0.333* | p=1 | 0 | 0 | NR
Tritapepe 2007^122^ | Retrospective comparative Treatment | 82.2 | 23 | 23 | 62.4 (9.4) | 62.2 (9.1) | 0.13 | 0.13 | p=1 | 0.087 | 0.087 | NR
Bowman 2008^124,†^ | Retrospective comparative Treatment | 100 | 36 | 385 | 58 (15) | NR | 0.083 | 0.044 to 0.047^†^ | NR | 0.111 | 0.055 | p=.15
Trowbridge 2008^125,†^ | Prospective comparative Treatment | NR | 17 | 187 | 70 (9) | 67 (11) | NR | NR | NR | NR | NR | NR

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies.

& Thromboembolic event rates were calculated by dividing the number of thromboembolic events by the sample size, not the number of patients who experienced thromboembolic events. Therefore, the rates reported here may differ slightly from those reported in each study. The tests of statistical significance presented are those reported by the individual studies and are not based upon the thromboembolic event rates reported in this table.

^ Diprose 2005^118^ excluded 1 patient who violated the study protocol after randomization. This patient was not evaluated for mortality or thromboembolic events.

* “Hospital mortality”. The mortality rates at 6 months were 0.583 in the rFVIIa group and 0.417 in the usual care group.

† These data were extrapolated as the range of possible mortality for the usual care group given the mortality rates reported for the rFVIIa group and the group of all patients combined.

NR=not reported; NS=not significant;

U median

[underlined: Mortality]. No study reported a significantly higher mortality rate in the rFVIIa group. Among the RCTs and good quality cohort studies, there were non-significant reductions in mortality with rFVIIa treatment compared to usual care in the Diprose RCT and Gelsomino cohort, exactly equal mortality rates between groups in the Karkouki cohort, and a non-significant increase in mortality in the Gill RCT. The remaining cohort studies, deemed fairon quality scoring,122,123 demonstrated equal mortality rates with rFVIIa use versus usual care. The meta-analysis of mortality for the RCT and good quality cohort studies found no difference in mortality with rFVIIa versus usual care (risk difference 0.007; 95 percent CI −0.049 to 0.063; P value for the Q statistic 0.63) (Figure 21), a finding that remained when sensitivity analyses were performed using the data from the Ma RCT211 published in Chinese ( risk difference 0.006; 95 percent CI −0.046 to 0.059; P value for the Q statistic 0.78) (Figure 22). To place the mortality differences in the context of the comparable findings for the other clinical indications, see Figure 5 above (in the Key Question section on intracranial hemorrhage).

Figure 21 Mortality in adult cardiac surgery

Figure 21 depicts a random effects model of mortality in adults from cardiac surgery. The summary statistics are as follows: Risk difference summary effect size 0.007 (95% CI: -0.0487; 0.063) P value for Q statistic: 0.63; I-Squared=0%

Figure 22 Sensitivity analysis: mortality in adult cardiac surgery that incorporates Chinese RCT data

Figure 22 depicts a random effects model of a sensitivity analysis of mortality in adult cardiac surgery that incorporates Chinese RCT data. The summary statistics are as follows: Risk difference summary effect size 0.006 (95% CI: -0.046; 0.059) P value for Q statistic: 0.78; I-Squared=0%

[underlined: Thromboembolic events]. The rFVIIa and control groups in the Diprose RCT had the same rates of thromboembolic events, whereas the Gill RCT had higher rates in the treatment group. The two good quality cohort studies together demonstrated a weak trend toward increased events with rFVIIa. The fair quality cohorts had low but equal rates in both groups. The meta-analysis of the RCTs and good quality cohort studies identified a higher rate of thromboembolic events in the rFVIIa group compared to controls(risk difference 0.053; 95 percent CI 0.01 to 0.096; P value for the Q statistic 0.99) (Figure 23). This finding was replicated on the sensitivity analyses that incorporated data from the Ma RCT 211 published in Chinese (risk difference 0.049; 95 percent CI 0.008 to 0.091) (Figure 24). To place the different thromboembolic event rates in the context of the comparable findings for the other clinical indications, see Figure 6 above (in the Key Question section on intracranial hemorrhage).

Figure 23 All thromboembolic events in adult cardiac surgery

Figure 23 depicts a random effects model of all thromboembolic events in adult cardiac surgery. The summary statistics are as follows: Risk difference summary effect size 0.053 (95% CI: 0.01 to 0.096) P value for Q statistic: 0.99; I-Squared=0%

Figure 24 Sensitivity analysis: all thromboembolic events in adult cardiac surgery that incorporates Chinese RCT data

Figure 24 depicts a random effects model of a sensitivity analysis of all thromboembolic events in adult cardiac surgery that incorporates Chinese RCT data. The summary statistics are as follows: Risk difference summary effect size 0.049 (95% CI: 0.008 to 0.091) P value for Q statistic: 0.98; I-Squared=0%

Indirect (surrogate) outcomes. These results are summarized in Table 41.

Table 41 Indirect outcomes in comparative studies of rFVIIa use in adult cardiac surgery

Article | Study Design and rFVIIa use | Mean rFVIIa dose(SD) [IQR] | Sample size | | Mean age (SD) [IQR] | | Mean RBC transfusion (SD) [IQR] | | | Mean ICU LOS (days) (SD) [IQR]
| | | rFVIIa | Usual care | rFVIIa | Usual care | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig
Diprose 2005^118^ | RCT Prophylaxis | 90 | 9 | 10 | 63^U^ [59–66] | 69.5^U^ [63.5–76.5] | 0^*^ [0–0.75] | 2^*^ [1–3.5] | p=0.11 * | 2.5^U^ [1–3.5] | 1^U^ [1–4] | p=.43
Gill 2009^119^ | RCT Treatment | 40 80 | 35 69 | 68 | 68 (12) 63 (16) | 62 (16) | ^ | ^ | ^ | “no diff”^†^ | “no diff”^†^ | NR
Karkouti 2005^120^ | Retrospective comparative Treatment | 51.1 | 51 | 51 | 56 | 59 | 2^U^ [0–3] | NR | NR | 6^U^ [3.5–11.5] | 3.5^U^ [1–10] | p<.05
Gelsomino 2008^121^ | Retrospective comparative Treatment | 18 [9–16] | 40 | 40 | 70.1 (9.2) | 73.2 (7.8) | 6.5^U^ [4–8.5] | 17^U^ [12–19.5] | p<.001 | 6.3^U^ [3.9–7.3] | 18.5^U^ [16.2–24] | p<.001
von Heymann 2005^123^ | Retrospective comparative Treatment | 89.3 | 24 | 24 | 63.5^ | 63.5^ | 4.0& | 2.6& | p=.44 | 14 [6.5–34.5]^R^ | 15 [6.0–29.5]^R^ | p=.96
Tritapepe 2007^122^ | Retrospective comparative Treatment | 82.2 | 23 | 23 | 62.4 (9.4) | 62.2 (9.1) | 9.1 (3.0) | 5.3 (3.2) | p<.001 | 8.2 (9.0) | 10.0 (8.4) | p=.08
Bowman 2008^124,†^ | Retrospective comparative Treatment | 100 | 36 | 385 | 58 (15) | NR | 3.1^#^ | NR | NR | NR | NR | NR
Trowbridge 2008^125,†^ | Prospective comparative Treatment | NR | 17 | 187 | 70 (9) | 67 (11) | 0.6 (1.2)^**^ | 5.4 (3.5)^**^ | p<.001 | NR | NR | NR

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

* Intention to treat data was used (rFVIIa group sample size equals 10 instead of 9). One patient who violated the study protocol in Diprose 2005^118^ was excluded from the analysis of mortality, thromboembolic events, and ICU length of stay, but was included in the intention to treat analysis of RBC transfusions. If this patient is excluded, median RBC transfusions are 0 units (range: 0–0 units) in the rFVIIa group and 2 units (range 1 to 3.5 units) in the usual care group (p=.03).

^ Total blood transfusion volume (not isolated to RBCs): 40 ug/kg rFVIIa, 640 mL [IQR 0–1920] (p= 0.047 versus usual care); 80 ug/kg rFVIIa, 500 mL [IQR 0–1750] (p=0.042 versus usual care); usual care, 825 mL [IQR 326.5–1893].

† There was “no difference” noted in ICU length of stay between groups in the trial synopsis posted on the manufacturer’s website. This outcome was not reported in the published article.

& Estimated graphically from figure 2 in von Heymann 2005^123^

# Estimated graphically from figure 1 in Bowman 2008^124^.

** Post-CPB transfusion without adjustment for timing of rFVIIa administration.

NR=not reported; NS=not significant;

U Denotes median

R Range instead of IQR.

[underlined: RBC transfusion during the 24-hour post-operative period]. The Karkouti study did not report comparative data on this outcome. The Diprose RCT and the only good quality cohort study to report on the outcome, the Gelsomino cohort, respectively demonstrated a non-significant and significant difference between groups that favored a reduction with rFVIIa use (p values 0.11 and <0.001, respectively). While the Gill RCT did not report on isolated RBC transfusions, it did report significant differences between the two treatment groups (40 and 80 μg/kg) and controls in total blood transfusion volume. The Ma RCT (published in Chinese and used only for sensitivity analyses) reported a significant reduction in units of RBCs transfused (rFVIIa 3.5 (SD 2.2) versus control 6.3 (SD 3.1) (p<0.01)).211 There were inconsistent findings among the remaining studies—namely, the fair quality cohorts. The von Heymann study found no difference between groups, and the Tritapepe study found a significant effect against the rFVIIa group (i.e., increased transfusions with treatment).

[underlined: ICU length of stay]. The Diprose RCT found no significant difference between groups, although the absolute difference in means indicated an increased ICU LOS within the rFVIIa group. The publication of the Gill RCT119 does not comment on ICU LOS, but the synopsis on the manufacturer’s website states that there was “no difference” between groups for this outcome.214 The Ma RCT (published in Chinese and used only for sensitivity analyses) reported a significantly shorter ICU LOS for the rFVIIa group (2.7 day (SD 0.5) versus 3.3 days (SD 0.7) for controls (p<0.05)).211 There were inconsistent findings among the cohort studies as well. The good quality Karkouti cohort study identified a significantly longer ICU LOS for rFVIIa patients compared to controls. However, the other good quality cohort study by Gelsomino had significant findings in the opposite direction—in favor of reduced time for the treatment group. The Tritatpepe study had non-significant findings in the same direction, whereas the remaining cohort study by von Heymann found no difference between groups.

Consideration of poor quality comparative observational studies. In the poor quality comparative observational studies by Bowman124 and Trowbridge,125 the findings on mortality, thromboembolic events, and RBC transfusions were generally consistent with those described above (Tables 40 and 41). Other outcomes were not reported.

### Other Considerations

Timing of administration. The Karkouti cohort study120 overlapped substantially with another study by the same group,215 which was excluded from subsequent analysis on the basis of that overlap and because it focused on “determinants of complications” rather than the comparison of rFVIIa with usual care and had methodological limitations. Nevertheless, it highlighted an important question regarding the timing of treatment use of rFVIIa in cardiac surgery patients.

The study findings should be interpreted with caution, but did identify a non-significant increased risk of adverse events when rFVIIa was given “late” in the resuscitation—with “late” defined as infusion after nine or more units of RBCs had already been administered. None of the included studies performed a similar evaluation of the impact of timing of rFVIIa administration on outcomes.

### Comparison to Premier Database

The age of study patients (mid 60s) was comparable to the mean age of 65 years for the Premier patients. The mortality rate of 0.23 among the Premier patients was higher than the rate found for rFVIIa patients in the RCTs but relatively comparable to those identified for the cohort studies. According to the Premier database, rates of use for the adult cardiac surgery indication have continued to increase in the community (with a much slower rate of increase followed by a recent leveling off for pediatric cardiac surgery patients who are discussed further in the subsequent section)(Figure 20).

Figure 20 Premier database rFVIIa use in adult and pediatric cardiac surgery

Figure 20 depicts the Premier database rFVIIa rise in use in adult and pediatric cardiac surgery, 2000-2008. According to the Premier database, rates of use for the adult cardiac surgery indication have continued to increase in the community (with a much slower rate of increase followed by a recent leveling off for pediatric cardiac surgery patients who are discussed further in the subsequent section).

### Strength of Evidence

The strength of evidence assigned to the thromboembolic event outcome was moderate, based on the consistency and precision of findings on the meta-analyses of the higher quality studies for these outcomes (Table 42). The remainder of the outcomes were assigned a low strength of evidence based primarily on weaknesses in two strength of evidence domains: the risk of bias domain—which had ratings of a medium or high—and the precision domain—which had ratings of imprecise. The rating of imprecise was based on wide confidence intervals for the major outcomes which in turn were due to low event rates in studies that were underpowered to detect mortality and major morbidity outcomes.

Table 42 Strength of evidence for rFVIIa use in adult cardiac surgery

Outcome of Interest | Number of Studies | Number of Subjects | | Domains Pertaining to Strength of Evidence | | | | | | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Domains Pertaining to Risk of Bias | | | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Design | Quality | Overall Risk | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Mortality (in-hospital) | 2^118, 119^ | 113 | 78 | RCT | Good | Low | Consistent | Direct | Imprecise | No Effect | Unknown | Low
Mortality (in-hospital) | 4^120–123^ | 138 | 138 | COBS | Good | Medium | Consistent | Direct | Imprecise | No effect | Unknown | Low
Mortality (in-hospital) | 4^118–121^ | 204 | 169 | M-A | Good | Low | Consistent | Direct | Imprecise | No effect | Unknown | Low
Thromboembolic Events | 2^118, 119^ | 113 | 78 | RCT | Good | Low | Consistent | Direct | Imprecise | Weak increase with rFVIIa | Unknown | Moderate
Thromboembolic Events | 4^120–123^ | 138 | 138 | COBS | Good | Medium | Consistent | Direct | Imprecise | Weak increase with rFVIIa | Unknown | Moderate
Thromboembolic Events | 4^118–121^ | 204 | 169 | M-A | Good | Low | Consistent | Direct | Precise | Increase with rFVIIa | Unknown | Moderate
Units of RBCs Transfused | 1^118^ | 10 | 10 | RCT | Fair | Medium | Unknown | Indirect | Imprecise | Weakly favors rFVIIa | Unknown | Low
Units of RBCs Transfused | 3^120, 122, 123^ | 98 | 98 | COBS | Fair | High | Inconsistent | Indirect | Imprecise | No effect | Unknown | Low
ICU Length of Stay | 1^118^ | 9 | 10 | RCT | Fair | Medium | Unknown | Indirect | Imprecise | Weak increase with rFVIIa | Unknown | Low
ICU Length of Stay | 4^120–123^ | 138 | 138 | COBS | Good | Medium | Inconsistent | Indirect | Imprecise | No effect | Unknown | Low

RCT=randomized controlled trial; ICU=intensive care unit; COBS=comparative observational study; RBCs=red blood cells. See Tables 4 to 7 for definitions of study quality and strength of evidence domains and designations.

### Applicability

The overall applicability of the evidence for this indication is fair for both prophylactic and treatment use in the population targeted—adult patients undergoing cardiac surgery, including more straightforward procedures (e.g., isolated CABG) and complex surgeries (e.g., ascending aortic dissection repair) (Table 43). Such study populations are diverse, giving them good applicability. The relatively narrow rFVIIa dose range that was studied may also be relevant to practice. However, the variability among studies in use of rFVIIa for prophylaxis versus treatment may be a limitation. The follow-up time was no longer than one month in any study, and the methods of ascertainment for harm was generally not well described, which limits applicability. The study settings were primarily academic centers, which may be more applicable to regional referral centers than community hospitals.

Table 43 Applicability assessment of studies on adult cardiac surgery

Available Evidence | Overall Implications for Applicability
Population
Adults undergoing cardiovascular surgery, in many cases complex procedures, including ascending aortic dissection repair, but also including more straightforward surgeries, such as isolated CABG Mean age 64 years High mortality rate (13 percent) in patients receiving rFVIIa in response to bleeding Patients generally with intact clotting systems at baseline, but also with effects of CPB (e.g., residual mpact of intraoperative heparin, hypothermia, etc.) and possible prior use of antiplatelet agents Minimal exclusions overall, but usually no underlying coagulopathy and RCTs excluded patients with prior thrombotic disorders | Other approaches available to minimize blood loss Lack of comparison between prophylactic use and use for treatment
Interventions
Prophylactic use of rFVIIa as a single dose of 90 mcg/kg prior to surgery Low dose treatment doses of 18 mcg/kg Higher dose treatment doses of 40 to 90 mcg/kg | Dose for prophylaxis is narrow and comparable to prophylactic doses used in studies on other indications and in practice Doses for treatment is lower than observed for treatment in other situations
Comparator
Usual care via randomization or matched controls | Other prophylactic and therapeutic hemostatic agents are potential comparators, but not used in this setting
Outcomes
Primary outcome: Red blood cell transfusions over 24 hours (in most studies) Secondary outcomes: mortality, thromboembolic events, ICU length of stay, operative time, coagulation lab parameters | Surrogate/indirect outcomes related to process of care without direct link to clinical outcomes Insufficient sample size to assess some clinical outcomes No measure of patient functional status
Timing and intensity of follow-up
Follow-up for duration of hospitalization or 30 days Seldom had protocol for ascertainment of harms | Longer term outcomes and a protocol for ascertainment of harms is desirable
Setting
Academic hospitals in the U.S., U.K., and Italy that serve as regional referral centers | Likely applicable to U.S. regional referral centers, perhaps less applicable to community hospitals

### Conclusions

There is evidence of moderate strength to suggest that the use of rFVIIa in adult cardiac surgery increases the rate of thromboembolic events compared to usual care. The strength of evidence was low for the remainder of outcomes, including for the finding of no effect of rFVIIa use on mortality. Among the RCTs and higher quality cohort studies, there was a trend toward reduced transfusion requirements with therapy, but no difference in ICU length of stay. Thus, current evidence of moderate strength (for thromboembolic events) or low strength (for all other outcomes) suggests that neither benefits nor harms substantially exceed each other. Study patients were similar in age to those in the Premier database. Compared to Premier patients, those in the cohort studies had comparable mortality rates, whereas those in the RCTs had somewhat lower mortality rates. The importance and nature of interactions between the timing of treatment use of rFVIIa and important clinical outcomes remain uncertain.

## Key Question 4.b.ii. Pediatric cardiac surgery and comparative effectiveness of rFVIIa

### Background

The infant population that requires cardiac surgery to correct congenital heart defects is particularly susceptible to dilutional coagulopathies that can cause excessive bleeding. RBC or whole blood transfusions are frequently required during operative or post-operative periods. No hemostatic agents have been found to be consistently useful in such surgeries. While a meta-analysis of aprotinin compared to usual care demonstrated reduced need for transfusions,216 these findings are not uniform217 and the drug is no longer available in the U.S. due to safety concerns. Multiple studies have shown that DDAVP does not reduce transfusion requirements during surgery for children with congenital heart disease.218–220 Pediatric cardiac surgery is further complicated by the frequent need post-surgery for the infant to remain on extracorporeal membrane oxygenation (ECMO) machines, despite the well recognized increased risk of thromboembolism with ECMO use.221

Usual care during the time frame of the included study. Pediatric cardiac surgeons differ in their preference for packed RBCs versus whole blood for transfusion support during surgery based on conflicting evidence in recent trials.222,223 Furthermore, recent studies have begun to explore whether transfusion use in pediatric cardiac surgery is associated with adverse effects, such as an increased risk of infection, similar to what has been suggested in the adult cardiac surgery literature.224

### RCT Design and Intervention

We found only one study on prophylactic use of rFVIIa in pediatric cardiac surgery, a poor quality RCT. This small, double-blind, placebo-controlled trial by Ekert did not report any Novo Nordisk sponsorship.137 It initially enrolled 82 patients, but six patients (four in the usual care group and two in the rFVIIa group) “did not receive trial medication” and were subsequently excluded from the intention-to-treat analysis, which left 36 control and 40 rFVIIa patients to be evaluated. Treatment with 40 μg/kg of rFVIIa (or placebo) was administered immediately after termination of CPB in children under one year of age who were undergoing repair of complex congenital heart defects. A second dose could be administered 20 minutes later in the operating room at the discretion of the surgeons. A third dose does not appear to have been required in any case. The mean cumulative dose administered was 63 μg/kg. Groups were similar at baseline in age, weight, type of surgery, and CPB time. The primary outcome was time to chest closure. The study also reported on outcomes of transfusion requirements of “blood ” (which could include packed cells or whole blood) and thromboembolic events. It did not explicitly comment on mortality. There was no mention of ECMO use in the study(Table 44). While attempts at a six-week follow-up were made, these were largely unsuccessful because of considerable missing data.

Table 44 General characteristics of comparative studies on off-label rFVIIa use for pediatric cardiac surgery

Article | Study Design | Study Setting and Time Period | Sample Size and Dose (μg/kg) | Population Characteristics | | Outcomes | Evaluated
| | | | Mean Age(SD) [Range] | Inclusion/Exclusion Criteria | Direct | Indirect
Ekert 2006^137^ | RCT Prophylaxis | 1 center Victoria, Australia Time period NR | All Rx: 40 Ucare: 35 Dose: 63.0 ug/kg | Rx: 4.0 months Ucare 3.9 months | Inclusion: -children under 1 year with complex congenital heart disease requiring surgery with CPB Exclusion: -liver failure -known thrombotic disorder -prior treatment with antifibrinolytic agents -indication for a Norwood procedure -patients on ventilation assistance -occurrence or preoperative sepsis or coagulopathy -expected lifespan of <=3 months | Adverse events including TE events | Transfusion requirements^††^ Blood loss Time to chest closure
Tobias 2004^139,†^ | Retrospective comparative Treatment | 1 center Santo Domingo, Dominican Republic 1/2003 | All Rx: 9 Ucare: 8 Dose: 90 ug/kg | Rx: 9 years (4) Ucare: 10 years (3) | Inclusion: -children who received rFVIIa and with postoperative bleeding of at least 4 mL/kg/hm for 3h consecutively Controls: contemporaneous cohort who had lower bleeding rates and did not receive rFVIIa | Adverse events including TE events | Blood loss Need for surgical re-exploration
Agarwal 2007^138,†^ | Retrospective comparative Treatment | 1 center Nashville, TN, USA 1/2000–12/2004 | All Rx: 24 Ucare: 22 Mean Dose: 43 ug/kg SD: 22.9 ug/kg | Rx: 9.5 days^U^ [4–3,285] Ucare: 7 days^U^ [2–240] | Inclusion: -children who received rFVIIa without a known bleeding disorder and with “severe” postoperative mediastinal bleeding, defined for neonates/infants as over 10 mL/h and for others as over 100 mL/h -includes children placed on ECMO after surgery Controls: contemporaneous cohort who met above criteria but did not receive rFVIIa | TE events | Transfusion requirements^††^ Blood loss Need for surgical re-exploration
Niles 2008^140,†^ | Retrospective comparative Treatment | 1 center Iowa City, IO, USA 2004–2006 | All Rx: 15 Ucare: 15 Dose not reported | Rx: 60 days (99); 5293 days (471)** Ucare: 16 days (19); 4531 days (2758)** | Inclusion: -cardiac surgery requiring CPB Controls: historical controls who underwent cardiac surgery requiring CPB and were matched for weight > or < 30 kg | Mortality TE events

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

SD=standard deviation; Rx=treatment group(s); Ucare=usual care; TE=thromboembolic;

†† Examples of transfusion requirements are red blood cells and fresh frozen plasma

U Median

Place of studies within analytic framework. The Ekert RCT evaluated prophylactic use of rFVIIa in pediatric cardiac surgery (versus treatment or end-stage use, which are other potential uses, as outlined in our Analytic Framework (Figure 1)).

Comparison to studies on other indications. This was the only included study on a solely pediatric patient population, in this case infants. The mean rFVIIa dose of 63 μg/kg was similar to the doses used in adults studies of prophylactic use.

### Outcomes

The study identified no thromboembolic events and did not explicitly report mortality (Table 45). With respect to the primary endpoint, rFVIIa patients had a longer time to chest closure than did controls (98.8 minutes (SE 27.3) versus 58.3 minutes (SE 29.2), p=0.026). Nonetheless, there was a non-significant decrease in transfusion requirement for RBCs and/or whole blood in the rFVIIa group (Table 46).

Table 45 Mortality and thromboembolic events in RCT on rFVIIa use in pediatric cardiac surgery

Article | Study Design rFVIIa use | Mean rFVIIa Dose (μg/kg) (SD) [Range] | Sample size | | Mean age (SD) | | Mortality rate | | | Thromboembolic events rate&
| | | rFVIIa | Usual care | rFVIIa | Usual care | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig
Ekert 2006^137^ | RCT Prophylaxis | 63 (20.2) | 40 | 36 | 4 months | 3.9 months | NR | NR | NR | 0 | 0 | NR
Tobias 2004^139,†^ | Prospective comparative Treatment | 90 | 9 | 8 | 9 years (4) | 10 years (3) | NR | NR | NR | 0 | NR | NR
Agarwal 2007^138,†^ | Retrospective comparative Treatment | 43 (23) | 24 | 22 | 10 days [4–32850 | 7 days [2–240] | NR | NR | NR | 0.25 | 0 | NR
Niles 2008^140,†^ | Retrospective comparative Treatment | [76–282]; [26–956] | 15 | 15 | 60 days (99); 5293 days (471)^**^ | 16 days (19); 4531 days (2758)^**^ | 0 | 0 | NR | 0 | 0 | NR

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies.

& Thromboembolic event rates were calculated by dividing the number of thromboembolic events by the sample size, not the number of patients who experienced thromboembolic events. Therefore, the rates reported here may differ slightly from those reported in each study. The tests of statistical significance presented are those reported by the individual studies and are not based upon the thromboembolic event rates reported in this table.

** Patients were divided into 2 groups: those <30 kg (N=11) and those>30 kg (N=4), respectively;

NR=not reported;

Table 46 Indirect outcomes in RCT on rFVIIa use in pediatric surgery

Article | Study Design rFVIIa use | Mean rFVIIa Dose (μg/kg) (SD) | Sample size | | Mean age (SD) | | RBC transfusion (mL) (SD) [Range] | | | Time to chest closure (minutes) (SD)
| | | rFVIIa | Usual care | rFVIIa | Usual care | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig
Ekert 2006^137^ | RCT Prophylaxis | 63 (20.2) | 40 | 36 | 4 months | 3.9 months | 77 [25–250] | 127 [12–400] | p=.15 | 98.8^*^ (27.3)^ | 55.3^*^ (29.2)^ | p=.026^*^
Tobias 2004^139,†^ | Prospective comparative Treatment | 90 | 9 | 8 | 9 years (4) | 10 years (3) | NR | NR | NR | NR | NR | NR
Agarwal 2007^138,†^ | Retrospective comparative Treatment | 43 (23) | 24 | 22 | 10 days [4–32850 | 7 days [2–240] | 75.1 (75.3) | 153.7 (132.2) | p<.001 | NR | NR | NR
Niles 2008^140,†^ | Retrospective comparative Treatment | [76–282]; [26–956] | 15 | 15 | 60 days (99); 5293 days (471)^**^ | 16 days (19); 4531 days (2758)^**^ | NR | NR | NR | NR | NR | NR

† These studies did not meet inclusion criteria for detailed review in the comparative effectiveness analyses due to being poor quality (Table 14), but are included in the qualitative sensitivity discussions for this indication (in the section above, “Consideration of poor quality comparative observational studies”) and in the overall harms analyses near the end of this report.

Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies.

^ Denotes standard error

* Intention to treat data was used. Sample size=35 for usual care group because one patient had no time to chest closure data. If “per protocol” data are used (sample size=23 rFVIIa; 18 usual care) mean time to chest closure is 62.4 (5.6) in the rFVIIa group and 57.1 (6.4) in the usual care group (p=.052). Those excluded from the per protocol analysis fulfilled the primary and secondary efficacy endpoints, but either did not have 6 week followup (n=22) or had a delay in short-term followup (n=12).

** Patients were divided into 2 groups: those <30 kg (N=11) and those>30 kg (N=4), respectively.

Consideration of poor quality comparative observational studies. Unlike the RCT, the poor quality comparative observational studies by Tobias,139 Agarwal, 138 and Niles 140 evaluated treatment use of rFVIIa. Nonetheless, their findings on thromboembolic events and RBC transfusions were consistent with those described above (Tables 44 and 45), with the possible exception of the Agarwal study, which noted a higher rate of thromboembolic events in patients who received rFVIIa versus usual care (6 of 24 (25 percent) and 0 of 22, respectively) and also raised the possibility of an increased risk of severe events among the subgroup of patients on ECMO, which is discussed in the section immediately below. Among these studies, only the one by Tobias reported mortality data, noting no deaths in either group. Other outcomes were not reported.

### Other Considerations

Risk of thromboembolic complications in the setting of ECMO use. A comparative cohort study by Agarwal et al. that did not meet criteria for inclusion in the effectiveness review due to methodological limitations nonetheless raises important questions about a subgroup of patients who might experience increased risk for harm within the population of infants undergoing congenital heart surgery.138 The Agarwal study evaluated a subgroup of 12 patients on ECMO who received therapeutic rFVIIa for bleeding after CPB completion, two of whom experienced life-threatening thromboembolic adverse events. In the first, the ECMO circuit clotted to the point where blood flow was compromised and the infant required emergent resuscitation and exchange of the circuit. The second patient, who underwent unsuccessful placement of a femoral arterial line after surgery and then received rFVIIa, developed an ipsalateral ischemic lower extremity, which required amputation, as well as both atrial and pericardial thrombi, which required surgical evacuation. In contrast, none of the 15 control patients on ECMO who received usual care were noted to have thromboembolic events of any kind. Given methodological limitations and small sample sizes, these findings should be interpreted with due caution.

### Comparison to Premier Database

The Premier database indicates a low but steady level of use of rFVIIa among pediatric cardiac surgery patients(Figure 20). The mortality rate of 0.22 in the Premier database cannot be comparated to any mortality rate in the RCT, because the RCT did not report this outcome. The mean age of study patients (3.9–4.0 months) was lower than the mean age of Premier patients (2.6 years). Whereas study patients were receiving their first surgical intervention at the time of rFVIIa administration, the Premier database may include patients undergoing repeat cardiac procedures, because the full repair of congenital heart defects often involves staged surgeries performed over time, which may explain their older age compared to study patients.

### Strength of Evidence

The strength of evidence was insufficient for all outcomes. This determination was made on the basis of having only one small, poor quality study for this indication, which put it at high risk for bias and limited its precision (Table 47).

Table 47 Strength of evidence for rFVIIa use in pediatric cardiac surgery

Outcome of Interest | Number of Studies | Number of Subjects | | Domains Pertaining to Strength of Evidence | | | | | | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Domains Pertaining to Risk of Bias | | | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Design | Quality | Overall Risk | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Mortality | 1^137^ | 40 | 36 | RCT | Poor | No Data | No Data | No Data | No Data | No Data | No Data | Insufficient
Thromboembolic Events | 1^137^ | 40 | 36 | RCT | Poor | High | Unknown | Direct | Imprecise | Unknown | Unknown | Insufficient
Units of WholeBl/RBCs Tx | 1^137^ | 40 | 36 | RCT | Poor | High | Unknown | Indirect | Imprecise | Weakly Favors rFVIIa | Unknown | Insufficient
Time to Chest closure | 1^137^ | 40 | 36 | RCT | Poor | High | Unknown | Indirect | Imprecise | Increase with rFVIIa | Unknown | Insufficient

RCT=randomized controlled trial; WholeBl=whole blood; RBCs=red blood cells. See Tables 4 to 7 for definitions of study quality and strength of evidence domains and designations.

### Applicability

The overall applicability of the evidence for this indication is fair for prophylactic use in the population targeted—infant patients with congenital heart defects requiring cardiac surgery for repair. This population, while limited in absolute number, has good applicability to similar populations at specialized referral centers like the institution that was the setting for the RCT. The low dose of rFVIIa is likely applicable as an appropriate amount for prophylaxis. The emphasis on indirect outcomes rather than mortality and morbidity outcomes is a limitation to applicability. While attempts at adequate follow-up were made, these were unsuccessful, and the method of ascertainment of harms was not described, making the follow-up applicability poor (Table 48).

Table 48 Applicability assessment of study of pediatric cardiac surgery

Describe Available Evidence | Describe Overall Implications for Applicability
Population
Patients under 1 year of age undergoing initial surgery for correction of a range of congenital cardiac abnormalities Mean age 4 months, mean weight 5.2 kg Patients with intact clotting systems Exclusions: Patients on anticoagulation or with limited life expectancy | The population included may be infrequent in clinical practice outside of major regional referral centers for pediatric cardiac surgery but compose an important subgroup of cardiac surgery patients
Intervention
An initial prophylactic dose of 40 mcg/kg at heparin reversal then repeated if needed (55 percent) for mean dose 63 μg/kg Detailed protocol of study visits | Dose is low compared to use as treatment
Comparator
Usual care via randomization | Other prophylactic hemostatic agents potential comparators, but not used in this setting
Outcomes
Primary outcomes: Time to chest closure Secondary outcomes: Blood loss, transfusion requirement, length of stay, operative time, thromboembolic events, coagulation lab parameters | Surrogate/indirect outcomes related to process of care without direct link to clinical outcomes Insufficient sample size to meaningfully assess clinical outcomes
Timing and intensity of follow-up
Initially short follow-up, but then with 6 week follow-up at return visit (but with considerable missing data) Lack of detailed protocol or reporting of thromboembolic events or other harms | More consistent, longer term outcomes desirable
Setting
Highly specialized Australian pediatric surgical center | Likely applicable to similar cardiovascular surgery referral centers

### Conclusions

Current evidence is insufficient for comparing the harms and benefits of rFVIIa use in infant patients undergoing cardiac surgery for congenital heart defect repair. The importance and nature of interactions between rFVIIa administration, ECMO use, and the risk of thromboembolic events remain uncertain.

## Key Question 4.c. Prostatectomy and comparative effectiveness of rFVIIa

### Background and Changes in Usual Care

The usual care of patients who require prostatectomy has changed considerably over the time period encompassing and since the performance of the Friederich RCT141 on rFVIIa use in prostatectomy (the one included study for this indication). Whereas radical retropubic prostatectomy and the Millin prostatectomy were frequent in decades past, they have been supplanted in most centers by laparoscopic approaches, which are associated with significantly less bleeding and fewer transfusions.225 For example, the authors of a letter to the editor on the Friederich RCT noted that they do not routinely prepare blood for transfusion prior to their procedures, because in most surgeries they have no transfusion requirements,226 which has been the case for others as well.227 Other changes in surgical approaches, including the use of robotics, have greatly reduced blood loss and hence transfusion requirements. These changes in practice likely account for the negligible use of rFVIIa noted in the Premier database.

### RCT Design and Intervention Characteristics

The only identified study of rFVIIa use in prostatectomy was the small Friederich RCT 141 that did not report any Novo Nordisk sponsorship and was deemed to be of fair quality (Table 49). It evaluated placebo versus prophylactic use rFVIIa in patients who were not on anticoagulation and were undergoing one of two possible procedures: radical retropubic prostatectomy for prostate cancer or the Millin procedure for benign prostatic hypertrophy. Study drug or placebo was administered after lymph node dissection in the former and placement of guiding sutures in the latter. The RCT enrolled 12 usual care patients and an aggregate of 24 rFVIIa patients, of whom eight received 20 μg/kg and 16 received 40 μg/kg, with the patients who received the different procedures being well balanced between groups. Groups also appeared well balanced at baseline on age and weight, but there was no other information given on other potentially relevant characteristics. Analyses were intention-to-treat and follow-up occurred at 10 days. There was no single primary outcome identified, but the study reported on RBC transfusion requirements, mortality, thromboembolic events, and the duration of operation (OR time).

Table 49 General characteristics of comparative studies on off-label rFVIIa use for prostatectomy

Article | Study Design | Study Setting and Time Period | Sample Size and Dose (μg/kg) | Population Characteristics | | Outcomes Evaluated
| | | | Mean Age (SD) [Range] | Inclusion/Exclusion Criteria and Other Patient Characteristics | Direct | Indirect
Friederich 2003^141^ | RCT Prophylaxis | 1 center Amsterdam, Netherlands Time period not reported. | All Rx: 24 20: 8 40: 16 Ucare: 12 | Rx: 40: 64 (8.5) Ucare: 63 (8.3) | Inclusion: -age 18–85 -scheduled to undergo radical retropubic prostatectomy for prostate cancer, or Millin prostatectomy for prostate hypertrophy Exclusion: -treatment with anticoagulants within 48 hours preoperatively, or treatment with aspirin within 7 days preoperatively -know congenital or acquired hemostatic disorder -unstable coronary artery disease or angina pectoris class III/IV -history of venous thromboembolism of known thrombophilic state -known advanced liver disease, liver cirrhosis, or acute hepatitis | Mortality Adverse events including TE events | Transfusion requirements (e.g. RBCs, FFP) Blood loss Hospital length of stay Operating time

SD=standard deviation; Rx=treatment group(s); Ucare=usual care; NR=not reported; TE=thromboembolic; RBCs=red blood cells; FFP=fresh frozen plasma;

Place of studies within analytic framework. The Friederich RCT examined prophylactic use of rFVIIa in prostatectomy (versus treatment or end-stage use, which are other potential uses, as outlined in our Analytic Framework (Figure 1)).

Comparison to studies on other indications. Studies of adult cardiac and liver transplantation also evaluated prophylactic use of rFVIIa. The mean age of the prostatectomy patients (61–64) was comparable to that of the intracranial hemorrhage and adult cardiac surgery patients. The single-dose infusion of either 20 or 40 μg of rFVIIa encompassed the lowest mean dose of any indication.

### Outcomes

There were no deaths in either study group (Table 50). One patient in the 20 μg/kg dose group experienced a myocardial infarction at day 14, the only thromboembolic event identified in the study. The RBC transfusion requirements were significantly reduced in the rFVIIa group, as was the OR time (Table 51).

Table 50 Mortality and thromboembolic events in RCT on rFVIIa use in prostatectomy

Article | Study Design rFVIIa use | rFVIIa Dose (μg/kg) | Sample size | | Mean age (SD) | | Mortality rate | | | Thromboembolic events rate&
| | | rFVIIa | Usual care | rFVIIa | Usual care | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig
Friederich 2003^141^ | RCT Prophylaxis | 20 40 | 8 16 | 12 | 61 (8.9) 64 (8.5) | 63 (8.3) | 0 0 | 0 | NR | 0.125 0 | 0 | NR

Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the study.

& Thromboembolic event rates were calculated by dividing the number of thromboembolic events by the sample size, not the number of patients who experienced thromboembolic events. Therefore, the rates reported here may differ slightly from those reported in each study. The tests of statistical significance presented are those reported by the individual studies and are not based upon the thromboembolic event rates reported in this table.

Table 51 Indirect outcomes in RCT on rFVIIa use in prostatectomy

Article | Study Design rFVIIa use | rFVIIa indication and dose (μg/kg) | Sample size | | Mean age (SD) | | RBC transfusion (SD) | | | OR time (minutes) (SD)
| | | rFVIIa | Usual care | rFVIIa | Usual care | rFVIIa | Usual care | Sig | rFVIIa | Usual care | Sig
Friederich 2003^141^ | RCT Prophylaxis | 20 40 | 8 16 | 12 | 61 (8.9) 64 (8.5) | 63 (8.3) | 0.6 (0.3) 0 (0) | 1.5 (0.4) | p=.057 p=.0003 | 126 (21) 120 (15) | 180 (16) | p=.034 p=.014

Sig=tests of statistical significance between the usual care and rFVIIa group(s). The p-values presented are those reported by the individual studies.

### Comparison to Premier Database

The very few Premier database patients who received rFVIIa were older (mean age, 69 years) than the study patients (mean age, 61–64 years). There were no deaths in either sample.

### Strength of Evidence

The strength of evidence was insufficient for all outcomes (Table 52). While the RCT was fair in quality, the patient sample size was low, which limits certainty regarding effect size estimates. In addition, the low event rates for thromboembolic events and mortality outcomes contributed to the determination of imprecision for these outcomes.

Table 52 Strength of evidence for rFVIIa use in prostatectomy

Outcome of Interest | Number of Studies | Number of Subjects | | Domains Pertaining to Strength of Evidence | | | | | | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Domains Pertaining to Risk of Bias | | | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Outcome of Interest | Number of Studies | rFVIIa | Usual Care | Design | Quality | Overall Risk | Consistency | Directness | Precision | Estimated Magnitude of Effect | Effect of rFVIIa Dosage | Overall Strength of Evidence Grade
Mortality (10 day) | 1^141^ | 24 | 12 | RCT | Fair | Medium | Unknown | Direct | Imprecise | Unknown | Unknown | Insufficient
Thromboembolic Events | 1^141^ | 24 | 12 | RCT | Fair | Medium | Unknown | Direct | Imprecise | Unknown | Unknown | Insufficient
Units of RBCs Transfused | 1^141^ | 24 | 12 | RCT | Fair | Medium | Unknown | Indirect | Imprecise | Favors rFVIIa | Yes | Insufficient
OR Time | 1^141^ | 24 | 12 | RCT | Fair | Medium | Unknown | Indirect | Imprecise | Favors rFVIIa | No | Insufficient

RCT=randomized controlled trial; RBCs=red blood cells; OR=operating room. See Tables 4 to 7 for definitions of study quality and strength of evidence domains and designations.

### Applicability

Overall applicability of the evidence is poor for prophylactic use in the populations targeted—patients undergoing retropubic prostatectomy for prostate cancer or benign hyperplasia but not on anticoagulation (Table 53). The baseline transfusion requirements and amount of bleeding are much higher in the study patient population than in the general population of patients undergoing prostatectomy and study patients may be younger as well, both of which make the population applicability poor. In addition, the “usual care” approach to prostatectomy has evolved into something very different, in most cases, from the surgeries evaluated in the included RCT, thereby making the applicability of the comparator also poor. Specifically, surgeons now favor laparoscopic or robotic approaches and alternative surgeries that, on average, incur much less blood loss than their predecessor procedures, thus altering the context of rFVIIa administration. Regarding other criteria of applicability, the dose of rFVIIa was on the lower end of those observed, but was relatively narrow, granting it fair applicability. Other limitations to applicability include the emphasis on surrogate measures, the short follow-up time (10 days), and the setting of the study being an academic rather than community hospital, the latter of which is more common in practice.

Table 53 Applicability assessment of study on prostatectomy

Describe Available Evidence | Describe Overall Implications for Applicability
Population
Two distinct populations are studied: -Retropubic prostatectomy for cancer -Retropubic prostatectomy for benign hyperplasia -Patients with intact clotting system Exclusions: Patients on anticoagulation | rFVIIa use for this indication very rare in U.S. and evidence is not relevant Transfusion requirements and blood loss are much higher for the control group than they are in the general population of patients undergoing prostatectomy
Intervention
Prophylactic use of rFVIIa at 20 or 40 mcg/kg Usual care, including transfusion protocol | Dose is low compared to use as treatment or even to prophylactic use in other indications
Comparator
Usual care via randomization | Advances in usual care have led to the application of other surgical approaches that minimize blood loss (e.g., TURP, laparoscopic surgery) Other prophylactic hemostatic agents potential comparators, but not used in this setting
Outcomes
Primary outcomes: Red blood cell transfusions and perioperative blood loss Secondary outcomes: length of stay, operative time, thromboembolic events, coagulation lab parameters | Surrogate/indirect outcomes related to process of care without direct link to clinical outcomes Insufficient sample size to meaningfully assess clinical outcomes
Timing and intensity of follow-up
Follow-up for duration of hospitalization (but with long, 10 day stays) Detailed protocol for ascertainment of MI and DVT | Longer term outcomes would be desirable
Setting
An academic hospital in the Netherlands | May have limited applicability to U.S. practices

### Conclusions

Current evidence is insufficient for comparing the harms and benefits of rFVIIa use in prostatectomy. In addition, the usual care for prostatectomy has likely evolved far beyond the standard of care employed in the RCT, making its relevance to current practice uncertain.

## Evaluation of Harms in Patients Who Received rFVIIa: Comparing the Premier, RCT, and Observational Study Data

Given concerns about the potential harms of rFVIIa, we sought to compare and contrast the absolute rates of morbidity and mortality associated with the use of rFVIIa across different types of evidence—that is, comparative and non-comparative data. We therefore examine mortality and thromboembolic event outcomes for the Premier database, RCTs, and observational studies. Additionally, we sought to evaluate the association of key predictors (study design, clinical indication for the use of rFVIIa, mean patient age, and total dose of rFVIIa) with these outcomes. For these analyses, we included data from the intervention arms of the RCTs and comparative observational studies, and from those non-comparative observational studies that reported relevant data for 15 or more patients (Table 54).

Table 54 Harms noted in the analysis of rFVIIa use

Study Design | Number of Studies | Study References | Mean Age Range (yrs) | Mean rFVIIa dose (mcg/kg) | Sample Size | Mortality | Thromboembolic Events
Intracranial hemorrhage
Premier | - | | 64.7 | - | 1235 | 0.34 | -
RCT | 4 (with 2 to 6 arms) | Mayer 2005a23, Mayer 2005b86, Mayer 2008^88^, Mayer 2006^87^ | 51 to 72 | 5 to 160 | 6 to 297 per arm | 0 to 0.38 | 0 to 0.33
Comparative observational | 4 | Hallevi 2008^92^, Brody 2005^91^, Pickard 2000^90^, Ilyas 2008^89^ | 60 to 77 | 80 | 5 to 46 | 0.13 to 0.43 | 0.04 to 0.2
Non-comparative Observational | 3 | Sutherland 2008^93^, Herbertson 2008^94^, Nussbaum 2009^95^ | 8 to 68 | 60 to 100 | 15 to 20 | 0.13 to 0.22 | 0 to 0.44
Body trauma
Premier | - | | 52.8 | - | 2136 | 0.33 | -
RCT | 1-Blunt | Boffard 2005^96^ | 33 | 400 | 69 | 0.25 | 0.03
| 1-Penetrating | Boffard 2005^96^ | 29 | 400 | 70 | 0.24 | 0.06
Comparative Observational | 5 | Rizoli 2006^97^, Fox 2009^99^, Dutton 2004^100^, Harrison 2005^101^, Nascimento 2008^181^ | 28 to 41 | 60 to 100 | 29 to 81 | 0.07 to 0.58 | 0.07–0.12^*^
Non-comparative Observational | 7 | Cameron 2007^102^, Felfernig 2007^103^, Thomas 2007^228^, Martinowitz 2005^104^, Perkins 2007^182,†^, Alten 2009^105^, Herbertson 2008^94^ | 7 to 44 | 68 to 140 | 15 to 242 | 0.13 to 0.42 | 0 to 0.11
Brain trauma
Premier | - | | 63.3 | - | 1224 | 0.34 | -
RCT | 1 (with 5 arms) | Narayan 2008^106^ | 51.5 | 40 to 200 | 11 to 14 per arm | 0 to 0.33 | 0 to 0.21
Comparative observational | 1 | Stein 2008^107^ | 29.9 | - | 29 | 0.34 | 0.21
Non-comparative Observational | 1 | Bartal 2007^109^ | 61 | 59 | 15 | 0.07 | 0
Liver transplantation
Premier | - | | 51.8 | - | 33 | 0.38 | -
RCT | 4 (with 1 to 3 arms) | Lodge 2005^110^, Planinsic 2005^111^, Pugliese 2007^112^, Liu 2009^113^ | 49 to 53 | 20 to 412 | 10 to 63 per arm | 0.02 to 0.08^#^ | 0 to 0.19^
Comparative Observational | 4 | Hendriks 2001^114^, Kalicinski 2005^116^, Niemann 2006^117^, De Gasperi 2005^115^ | 13 to 48 | 30 to 80 | 6 to 28 | 0 to 0.07 | 0 to 0.17
Adult cardiac surgery
Premier | - | | 65.3 | - | 2419 | 0.23 | -
RCT | 2 (with 1 to 2 arms) | Diprose 2005,^118^ Gill 2009^119^ | 63 to 64 | 40 to 90 | 9 to 68 | 0 to 0.11 | 0.06 to 0.22
Comparative Observational | 4 | Bowman 2008^124^, Gelsomino 2008^121^, von Heymann 2005^123^, Trowbridge 2008^125^ | 58 to 70 | 18 to 100 | 17 to 40 | 0.05 to 0.38 | 0 to 0.11
Non-comparative Observational | 13 | Karkouti 2006^215^, Tritapepe 2007^122^, Filsoufi 2006^126^, Gandhi 2007^127^, Hyllner 2005^128^, McCall 2006^129^, Raivio 2005^130^, Aggarwal 2004^131^, Karkouti 2008^132^, Dunkley 2008^133^, Bruckner 2009^134^, Masud 2009^135^, Hsia 2009^136^ | 51 to 68 | 15 to 103 | 16 to 503 | 0 to 0.87 | 0 to 0.39
Pediatric cardiac surgery
Premier | - | | 2.6 | - | 274 | 0.22 | -
RCT | 1 (with 1 arm) | Ekert 2006^137^ | 0.3 | 63 | 40 | - | 0
Comparative Observational | 3 | Agarwal 2007^138^, Tobias 2004^139^, Niles 2008^140^ | 0 to 9 | 60 to 286 | 4 to 24 | 0 | 0 to 0.08
Prostatectomy
Premier | - | | 68.9 | - | 15 | 0 | -
RCT | 1 (with 2 arms) | Friederich 2003^141^ | 61 to 64 | 20 to 40 | 8 to 16 | 0 | 0 to 0.13

* The rate of thromboembolic events is based on a continuation of Rizoli et al.97 with 72 patients.229

† Data on mortality and thromboembolic events from Perkins et al.182 (an overlapping non-comparative study) are used instead of Spinella et al.98 (a comparative observational study analysed in the body trauma section above) because the former has a larger sample size.

# Mortality is underestimated because 2 deaths each in Lodge et al.110 and Planinsic et al.111 were not reported by treatment arm.

^ Thromboembolic events are underestimated because only arterial thromboembolic events were counted in Planinsic et al.111

In prior sections of the report only comparative observational studies of fair or good quality were reviewed in detail. However, in this section all comparative observational studies are included, along with their non-comparative counterparts. Also note that we are unable to report on thromboembolic events following rFVIIa use in the Premier database.

### Findings

Across clinical indications, the mortality rate ranged extremely widely from 0 to 0.87 and the thromboembolic event rate ranged from 0 to 0.39, depending on the clinical indication for use of rFVIIa, age, dose, and study design. Figure 25 presents the adjusted mortality rates by age and indication for the rFVIIa groups in the RCTs—it shows the enormous heterogeneity of effects across indications. Adjusted thromboembolic rates varied similarly (Figure 26).

Figure 25 Adjusted mortality rate by age from the RCTs

Figure 25 presents the adjusted mortality rates by age and indication for the rFVIIa groups in the RCTs—it shows the enormous heterogeneity of effects across indications namely ICH, body trauma, brain trauma, liver transplantation, adult cardiac surgery, pediatric cardiac surgery, and prostatectomy. On the left, adjusted mortality rate (by control) ranges from -0.4 to 0.4. The bottom has ages, starting at 0. There are symbols for the following: ICH, body trauma, brain trauma, liver transplantation, adult cardiac surgery, pediatric cardiac surgery, and prostatectomy. With the exception of two points for liver transplantation, all other points are after about age 45. The greatest mortality rate is approximately just below 0.3 and is for ICH. All other points are between -0.2 and 0.2.

Figure 26 Adjusted all thromboembolic event rate by age from the RCTs

Figure 26 depicts the adjusted thromboembolic event rates by age and indication for the rFVIIa groups in the RCTs—it shows the enormous heterogeneity of effects across indications ICH, body trauma, brain trauma, liver transplantation, adult cardiac surgery, pediatric cardiac surgery, and prostatectomy. On the left, adjusted mortality rate (by control) ranges from -0.4 to 0.4. The bottom has ages, starting at 0. There are three points on the graph before the age of 40. There is an x for pediatric cardiac surgery at approximately 1 year of age and 0.0; the other two points are at approximately 23 and 37 near 0.0. The rest of the points are after approximately age 50. The highest point on the scatter plot is for ICH and is between 0.2 and 0.4 after age 60 and the lowest point on the scatter plot is for ICH and is just above --0.4 after age 60.

For each indication, Figures 27 and 28 present the mean mortality and thromboembolic event rates, respectively, by study design. In general, the mortality rates were lowest in the RCTs and highest in the Premier database. Similarly, in general, the thromboembolic rates were generally lowest in the RCTs and highest in the observational studies.

Figure 27 Weighted mean mortality (95 percent CI) by study design for each indication

Figure 27 depicts the weighted mean mortality (95 percent CI) by study design for each indicator: ICH, body trauma, brain trauma, liver transplantation, adult cardiac surgery, pediatric cardiac surgery, and prostatectomy. There are seven scatter graphs in this figure, one for each indicator. Each looks at a weighted mean mortality from 0.0 to 0.5 on the left side and RCT, Comp Obs, Non Comp Obs, and Premier Data along the bottom. In general, the mortality rates were lowest in the RCTs and highest in the Premier database.

Figure 28 Weighted mean total thromboembolic event rate (95 percent CI) by study design for each indication

Figure 28 depicts the weighted mean total thromboembolic event rate (95 percent CI) by study design for each indicator: ICH, body trauma, brain trauma, liver transplantation, adult cardiac surgery, pediatric cardiac surgery, and prostatectomy. There are seven scatter graphs in this figure, one for each indicator. Each looks at a weighted mean mortality from 0.0 to 0.25 on the left side and RCT, Comp Obs, and Non Comp Obs along the bottom. In general, the thromboembolic rates were generally lowest in the RCTs and highest in the observational studies.

Figures 29 through 32 present the mortality and thromboembolic rates by mean age and total rFVIIa dose. In general, there was no apparent pattern relating age and mortality or age and thromboembolic events, although it is notable that the ages tended to cluster for a given indication. There was also no apparent pattern between dose and mortality or dose and thromboembolic events (with the possible exception of brain trauma, which is discussed further below). Figure 33 displays the mortality by thromboembolic event rate, and, again, there was no readily apparent pattern of association.

Figure 29 Mortality by mean age per indication

Data points in this figure include only the intervention arms (i.e. rFVIIa patients) from comparative studies. A data point for each dosing arm is presented for RCTs with multiple dosing arms; thus, the number of studies may not equal the number of data points.

Figure 29 depicts mortality by mean age per indication for ICH, body trauma, brain trauma, liver transplantation, adult cardiac surgery, pediatric cardiac surgery, and prostatectomy. There are seven scatter graphs in this figure. On the left mortality ranges from 0.00 to 1.00. At the bottom, mean age begins at 0 and goes through 80. Data points in this figure include only the intervention arms (i.e. rFVIIa patients) from comparative studies. A data point for each dosing arm is presented for RCTs with multiple dosing arms; thus, the number of studies may not equal the number of data points. In general, there was no apparent pattern relating age and mortality, although it is notable that the ages tended to cluster for a given indication. There was also no apparent pattern between dose and mortality or dose and thromboembolic events (with the possible exception of brain trauma, which is discussed separately.

Figure 30 Mortality by rFVIIa dose per indication

Data points in this figure include only the intervention arms (i.e. rFVIIa patients) from comparative studies. A data point for each dosing arm is presented for RCTs with multiple dosing arms; thus, the number of studies may not equal the number of data points.

Figure 30 depicts mortality by rFVIIa dose per indication for ICH, body trauma, brain trauma, liver transplantation, adult cardiac surgery, pediatric cardiac surgery, and prostatectomy. There are seven scatter graphs in this figure. On the left is a mortality scale from 0.0 to 1.0 and at the bottom, rFVIIa Dose ranges from 1 to 400. Data points in this figure include only the intervention arms (i.e. rFVIIa patients) from comparative studies. A data point for each dosing arm is presented for RCTs with multiple dosing arms; thus, the number of studies may not equal the number of data points. In general, there was no apparent pattern relating age and mortality or age, although it is notable that the ages tended to cluster for a given indication. There was also no apparent pattern between dose and mortality or dose and thromboembolic events (with the possible exception of brain trauma, which is discussed separately.

Figure 31 Thromboembolic events by mean age per indication

Data points in this figure include only the intervention arms (i.e. rFVIIa patients) from comparative studies. A data point for each dosing arm is presented for RCTs with multiple dosing arms; thus, the number of studies may not equal the number of data points.

Figure 31 depicts thromboembolic events by mean age per indication for ICH, body trauma, brain trauma, liver transplantation, adult cardiac surgery, pediatric cardiac surgery, and prostatectomy. There are seven scatter graphs in this figure. On the left are thromboembolic event rates from 0.0 to .5 and at the bottom, mean ages from 0 to 80. Data points in this figure include only the intervention arms (i.e. rFVIIa patients) from comparative studies. A data point for each dosing arm is presented for RCTs with multiple dosing arms; thus, the number of studies may not equal the number of data points. In general, there was no apparent pattern relating age and thromboembolic events, although it is notable that the ages tended to cluster for a given indication. There was also no apparent pattern between dose and mortality or dose and thromboembolic events (with the possible exception of brain trauma, which is discussed separately.

Figure 32 Thromboembolic events by rFVIIa dose per indication

Data points in this figure include only the intervention arms (i.e. rFVIIa patients) from comparative studies. A data point for each dosing arm is presented for RCTs with multiple dosing arms; thus, the number of studies may not equal the number of data points.

Figure 32 depicts thromboembolic events by rFVIIa dose per indication for ICH, body trauma, brain trauma, liver transplantation, adult cardiac surgery, pediatric cardiac surgery, and prostatectomy. There are seven mini scatter graphs in this figure. At the left is a thromboembolic event rate from 0.0 to 0.5, and at the bottom are rFVIIa Doses from 0 to 400. Data points in this figure include only the intervention arms (i.e. rFVIIa patients) from comparative studies. A data point for each dosing arm is presented for RCTs with multiple dosing arms; thus, the number of studies may not equal the number of data points. In general, there was no apparent pattern relating age and thromboembolic events, although it is notable that the ages tended to cluster for a given indication. There was also no apparent pattern between dose and mortality or dose and thromboembolic events (with the possible exception of brain trauma, which is discussed separately.

Figure 33 Association of mortality and thromboembolic event rate

Data points in this figure include only the intervention arms (i.e. rFVIIa patients) from comparative studies. A data point for each dosing arm is presented for RCTs with multiple dosing arms; thus, the number of studies may not equal the number of data points.

Figure 33 depicts the association of mortality and thromboembolic event rates for ICH, body trauma, brain trauma, liver transplantation, adult cardiac surgery, pediatric cardiac surgery, and prostatectomy. There are seven scatter graphs in this figure with mortality on the left and ranging from 0.0 to 1.0 and thromboembolic event rates across the bottom and ranging from 0.0 to 0.5. Data points in this figure include only the intervention arms (i.e. rFVIIa patients) from comparative studies. A data point for each dosing arm is presented for RCTs with multiple dosing arms; thus, the number of studies may not equal the number of data points.

Intracranial Hemorrhage. In contrast to other clinical indications, most of the harms data for rFVIIa use in intracranial hemorrhage comes from RCTs rather than comparative observational studies (Figures 27 and 28 and Table 54). Four RCTs evaluated harms for ICH: in their various dosing arms mortality ranged from 0 to 0.375 and total thromboembolic events ranged from 0 to 0.33. Four comparative observational studies reported harms for ICH and, in a small number of patients, other forms of intracranial hemorrhage. Mortality ranged from 0.13 to 0.43, and total thromboembolic events ranged from 0.04 to 0.2. Mortality in the Premier database was higher (0.34) than in the aggregate RCTs and observational studies. Thromboembolic events were higher in the observational studies than in the RCTs.

The RCTs excluded patients on anticoagulants, whereas these patients were included in the observational studies and the Premier database. One observational study91 had a significantly higher mortality than the other studies (0.42). It specifically analyzed patients with warfarin-related ICH and other patients who were considered to be at “especially high risk” for hematoma growth.

Body trauma. Across study designs, mortality rates among patients receiving rFVIIa for body trauma were among the highest of all the clinical indications, although, again, the range was wide. The two RCTs reported the following event rates: mortality 0.25 and thromboembolism 0.03 in the blunt trauma trial and mortality 0.24 and thromboembolism 0.06 in the penetrating trauma trial. Twelve observational studies reported mortality and/or thromboembolic event rates among trauma patients. Rates for mortality ranged from 0.07 to 0.58 and thromboembolism ranged from 0 to 0.12. Mortality in the Premier database (0.33) was somewhat higher than that of the RCTs (Figures 27 and 28 and Table 54).

The wide range of mortality across study types may be due to differences in inclusion criteria. The RCT96 excluded patients over 65 years, those receiving greater than eight units of RBCs prior to arrival at the hospital, and those with severe acidosis or base deficit. Another study98, 182 of combat trauma patients reported that only 28 percent of patients would have met inclusion for the RCT.96 Several of the observational studies included patients on warfarin or other anticoagulants. As noted earlier in the report, we are aware of a recently concluded phase III trial of rFVIIa in trauma that also uses restrictive inclusion criteria—only two percent of patients from the largest Australian registry102 would have met its inclusion criteria.

The rate of thromboembolic events in trauma was somewhat lower than for other clinical indications. This may be the case because trauma patients were generally younger and healthier than patients receiving rFVIIa for other indications. It may also reflect differences in harms ascertainment, given the high rate of mortality in trauma (i.e., if patients die early, other harms may not be attributed to them). One observational study228 with a protocol for identifying thromboembolic complications among trauma patients who received rFVIIa (N=242) identified a thromboembolic event rate of 0.11—which was higher than the rates identified for the RCTs but still lower than the rates reported for other rFVIIa indications, particularly cardiac surgery.

Brain trauma. One RCT evaluated harms among rFVIIa patients with bleeding due to TBI. This study had five arms, each of which evaluated a different rFVIIa dose. Mortality in this study ranged from 0 to 0.33 between dosing arms and may be linear with dose, although the study was quite small, so that no definitive conclusions can be made. Interestingly, total thromboembolic events ranged from 0 to 0.21 and did not appear to be associated with dose. The comparative observational study and non-comparative observational study reported quite different mortality and thromboembolic rates from each other (0.34 and 0.07 for the former and 0.21 and 0 for the latter). Patients included in the Premier database had higher mortality (0.33) and were generally older than the patients in the RCTs (Figures 27 and 28 and Table 54).

Mortality in the comparative observational study107 was significantly higher than in the RCT.106 This may be due to differences in inclusion criteria: the RCT included patients with a Glasgow Coma Scale (GCS) of 4 to 14 and excluded patients with planned neurosurgery, whereas the observational study limited rFVIIa use to coagulopathic patient with possibly more severe TBI (GCS less than 9, INR greater than 1.4) who required neurosurgical management of their hemorrhage.

Liver Transplantation. Four RCTs evaluated liver transplantation patients: their reported mortality ranged from 0.02 to 0.08. However, two RCTs110, 111 did not report mortality by arm (treatment versus placebo); thus, this range underestimates the true mortality rate among patients receiving rFVIIa in RCTs. Rates of thromboembolic events ranged from 0 to 0.19. Again, this range underestimates the total thromboembolic event rate for patients in RCTs because one study111 did not report venous events by arm (treatment versus placebo). Four observational studies evaluated harm in liver transplantation: mortality ranged from 0 to 0.07, and the rate of thromboembolic events ranged from 0 to 0.17. Mortality was substantially higher in patients from the Premier database (0.38) than in other studies (Figures 27 and 28 and Table 54).

The treatment dose administered in the RCT by Lodge110 was substantially higher than in the other RCTs,111–113 and Lodge 110 reported a significantly higher rate of thromboembolic events—although it may be that the other studies simply under reported such harms. All studies of liver transplant recipients provided rFVIIa prophylactically and, in most cases, at lower doses (with the exception of the Lodge RCT) than in other indications. This may account, in part, for the relatively lower rates of mortality and thromboembolic harms among liver transplant recipients compared to patients who received rFVIIa for other indications.

Adult Cardiac Surgery. Two RCTs reported data on adult cardiac surgery. The reported mortality rates in the rFVIIa arms of the RCTs ranged from 0 to 0.11 and total thromboembolic event rates ranged from 0.06 to 0.22. Mortality in the Premier database (0.23) was high compared with the RCTs and comparative observational studies (Figures 27 and 28 and Table 54).

The mortality rates in the observational studies of cardiac surgery were generally higher than those reported in the RCTs (mortality, range 0 to 0.87). This may have to do with differences in inclusion criteria—namely, that the RCTs typically excluded the most severely ill patients, whereas observational studies often included such patients. For instance, one observational study 127 included only patients undergoing orthotopic heart transplant or LVAD implantation, and another122 enrolled patients undergoing aortic dissection repair.

Pediatric Cardiac Surgery. Harms were reported in the intervention groups of the one RCT and three observational studies of pediatric cardiac surgery. Overall, the rates of thromboembolic events were lower in the pediatric cardiac surgery studies than in the adult studies (Table 54). Mortality was not reported in the RCT, but was lower in the observational studies than in the adult studies or the Premier database.

Prostatectomy. There was one RCT of prostatectomy which reported no mortality and one myocardial infarction (Table 54).

### Conclusions

Because this analysis includes data from observational studies and the Premier database, as well as from RCTs, it usefully highlights areas of consistency and contrast among different data sources. Across all indications except for prostatectomy (where no deaths were reported in any data set), mortality rates among patients in the Premier database were uniformly higher than the mortality rates in the RCTs, emphasizing that patients receiving rFVIIa in practice may differ in important ways from those in the included trials. Such distinctions may alter the risk-benefit profile of rFVIIa administration for real-world populations. Because of the limitations of our data, we can not comment further on how to interpret these differences, except to say that extrapolation from our comparative effectiveness review to real-world contexts, where the patients appear generally to be older and sicker, should be undertaken with appropriate caution.