# References

1 Vandenbroucke JP, Psaty BM. Benefits and risks of drug treatments: how to combine the best evidence on benefits with the best data about adverse effects. JAMA. 2008;300(20):2417-2419. [pmid: 19033592].
2 Radley DC, Finkelstein SN, Stafford RS. Off-label prescribing among office-based physicians. Arch Intern Med. 2006;166(9):1021-1026. [pmid: 16682577].
3 Ma J, Lee KV, Stafford RS. Depression treatment during outpatient visits by U.S. children and adolescents. J Adolesc Health. 2005;37(6):434-442. [pmid: 16310120].
4 Alexander GC, Sehgal NL, Moloney RM, et al. National trends in treatment of type 2 diabetes mellitus, 1994–2007. Arch Intern Med. 2008;168(19):2088-2094. [pmid: 18955637].
5 Stafford RS. Regulating off-label drug use--rethinking the role of the FDA. N Engl J Med. 2008;358(14):1427-1429. [pmid: 18385495].
6 Walton SM, Schumock GT, Lee KV, et al. Prioritizing future research on off-label prescribing: results of a quantitative evaluation. Pharmacotherapy. 2008;28(12):1443-1452. [pmid: 19025425].
7 Red Book. Montvale, NJ. Thomson Healthcare. 2009.
8 Top 200 drugs used in hospitals in 2007. Drug Topics. Advanstar Communications. North Olmsted, Ohio. 2008. Available at: http://drugtopics.modernmedicine.com/drugtopics/data/articlestandard//drugtopics/262008/526563/article.pdf. Accessed: February 9, 2010.
9 Kessler CM, Mariani G. Colman RW, et al., editors. Clinical manifestations and therapy of the hemophilias. Hemostasis and Thrombosis: Basic Principles and Clinical Practice. 5 ed. Philadelphia. Lippincott-Raven. 2006:887-904.
10 Lusher JM. Inhibitor antibodies to factor VIII and factor IX: management. Semin Thromb Hemost. 2000;26(2):179-188. [pmid: 10919411].
11 Hay CRM, Brown S, Collins PW, et al. The diagnosis and management of factor VIII and IX inhibitors: a guideline from the United Kingdom Haemophilia Centre Doctors Organisation. British Journal of Haematology. 2006;133(6):591-605. [pmid: 16704433].
12 Negrier C, Dargaud Y, Bordet JC. Basic aspects of bypassing agents. Haemophilia. 2006;12(Suppl 6):48-52. discussion 52–43. [pmid: 17123394].
13 Ehrlich HJ, Henzl MJ, Gomperts ED. Safety of factor VIII inhibitor bypass activity (FEIBA): 10-year compilation of thrombotic adverse events. Haemophilia. 2002;8(2):83-90. [pmid: 11952842].
14 Mangano DT, Miao Y, Vuylsteke A, et al. Mortality associated with aprotinin during 5 years following coronary artery bypass graft surgery. JAMA. 2007;297(5):471-479. [pmid: 17284697].
15 Mangano DT, Tudor IC, Dietzel C. The risk associated with aprotinin in cardiac surgery. N Engl J Med. 2006;354(4):353-365. [pmid: 16436767].
16 Fergusson DA, Hebert PC, Mazer CD, et al. A comparison of aprotinin and lysine analogues in high-risk cardiac surgery. N Engl J Med. 2008;358(22):2319-2331. [pmid: 18480196].
17 Hoffman M, Monroe DM, Roberts HR. Human monocytes support factor X activation by factor VIIa, independent of tissue factor: implications for the therapeutic mechanism of high-dose factor VIIa in hemophilia. Blood. 1994;83(1):38-42. [pmid: 8274750].
18 Hedner U. Mechanism of action of factor VIIa in the treatment of coagulopathies. Semin Thromb Hemost. 2006;32(Suppl 1):77-85. [pmid: 16673269].
19 Welsby IJ, Monroe DM, Lawson JH, et al. Recombinant activated factor VII and the anaesthetist. Anaesthesia. 2005;60(12):1203-1212. [pmid: 16288618].
20 Hedner U, Kisiel W. Use of human factor-VIIa in the treatment of 2 hemophilia A patients with high titer inhibitors. Journal of Clinical Investigation. 1983;71(6):1836-1841. [pmid: 6408124].
21 Macik BG, Hohneker J, Roberts HR, Griffin AM. Use of recombinant activated factor VII for treatment of a retropharyngeal hemorrhage in a hemophilic patient with a high titer inhibitor. Am J Hematol. 1989;32(3):232-234. [pmid: 2816918].
22 Kristensen J, Killander A, Hippe E, et al. Clinical experience with recombinant factor VIIa in patients with thrombocytopenia. Haemostasis. 1996;26(Suppl 1):159-164. [pmid: 8904193].
23 Mayer SA, Brun NC, Begtrup K, et al. Recombinant activated factor VII for acute intracerebral hemorrhage. N Engl J Med. 2005;352(8):777-785. [pmid: 15728810].
24 Available at: http://www.novosevenrt.com/pdfs/PI_novosevenrt.pdf Accessed: February 9, 2010
25 Warren OJ, Alcock EM, Choong AM, et al. Recombinant activated factor VII: a solution to refractory haemorrhage in vascular surgery?. Eur J Vasc Endovasc Surg. 2008;35(2):145-152. [pmid: 17964194].
26 Karkouti K, Beattie WS, Crowther MA, et al. The role of recombinant factor VIIa in on-pump cardiac surgery: proceedings of the Canadian Consensus Conference. Can J Anaesth. 2007;54(7):573-582. [pmid: 17602044].
27 Stanworth SJ, Birchall J, Doree CJ, Hyde C. Recombinant factor VIIa for the prevention and treatment of bleeding in patients without haemophilia. Cochrane Database Syst Rev. 2007(2):CD005011.
28 Marti-Carvajal AJ, Salanti G, Marti-Carvajal PI. Human recombinant activated factor VII for upper gastrointestinal bleeding in patients with liver diseases. Cochrane Database Syst Rev. 2007(1):CD004887.
29 Special report: recombinant activated factor VII for uncontrolled bleeding in non-hemophiliac patients. Technol Eval Cent Asses Program Exec Summ. 2006;21(10):1-2.
30 Aguilar MI, Hart RG, Kase CS, et al. Treatment of warfarin-associated intracerebral hemorrhage: literature review and expert opinion. [erratum appears in Mayo Clin Proc 2007 Mar;82(3):387]. Mayo Clinic Proceedings. 2007;82(1):82-92. [pmid: 17285789].
31 Aledort LM. Comparative thrombotic event incidence after infusion of recombinant factor VIIa versus factor VIII inhibitor bypass activity [see comment]. Journal of Thrombosis & Haemostasis. 2004;2(10):1700-1708. [pmid: 15456478].
32 Cosmi B. Review: recombinant factor VIIa does not differ from placebo for prevention or treatment of bleeding in patients without hemophilia [comment]. ACP Journal Club. 2007;147(3):70. [pmid: 17975872].
33 Davis SM, Broderick J, Hennerici M, et al. Hematoma growth is a determinant of mortality and poor outcome after intracerebral hemorrhage. Neurology. 2006;66(8):1175-1181. [pmid: 16636233].
34 Diringer MN, Skolnick BE, Mayer SA, et al. Risk of thromboembolic events in controlled trials of rFVIIa in spontaneous intracerebral hemorrhage. Stroke. 2008;39(3):850-856. [pmid: 18239180].
35 Franchini M, Franchi M, Bergamini V, et al. A critical review on the use of recombinant factor VIIa in life-threatening obstetric postpartum hemorrhage. Seminars in Thrombosis & Hemostasis. 2008;34(1):104-112. [pmid: 18393147].
36 Franchini M, Manzato F, Salvagno GL, et al. Potential role of recombinant activated factor VII for the treatment of severe bleeding associated with disseminated intravascular coagulation: a systematic review. Blood Coagulation & Fibrinolysis. 2007;18(7):589-593. [pmid: 17890943].
37 Franchini M, Veneri D, Lippi G. The potential role of recombinant activated FVII in the management of critical hemato-oncological bleeding: a systematic review. Bone Marrow Transplantation. 2007;39(12):729-735. [pmid: 17417659].
38 Hanggi D, Steiger HJ. Spontaneous intracerebral haemorrhage in adults: a literature overview. Acta Neurochirurgica. 2008;150(4):371-379. discussion 379. [pmid: 18176774].
39 Hearnshaw S, Travis S, Murphy M. The role of blood transfusion in the management of upper and lower intestinal tract bleeding. Best Practice & Research in Clinical Gastroenterology. 2008;22(2):355-371.
40 Heier HE, Bugge W, Hjelmeland K, et al. Transfusion vs. alternative treatment modalities in acute bleeding: a systematic review [see comment]. Acta Anaesthesiologica Scandinavica. 2006;50(8):920-931. [pmid: 16923085].
41 Levi M, Peters M, Buller HR. Efficacy and safety of recombinant factor VIIa for treatment of severe bleeding: a systematic review. Critical Care Medicine. 2005;33(4):883-890. [pmid: 15818119].
42 Lam MSH, Sims-McCallum RP. Recombinant factor VIIa in the treatment of non-hemophiliac bleeding. Annals of Pharmacotherapy. 2005;39(5):885-891. [pmid: 15784806].
43 Levy JH, Fingerhut A, Brott T, et al. Recombinant factor VIIa in patients with coagulopathy secondary to anticoagulant therapy, cirrhosis, or severe traumatic injury: review of safety profile. Transfusion. 2006;46(6):919-933. [pmid: 16734808].
44 Mathew P. The use of rFVIIa in non-haemophilia bleeding conditions in paediatrics. A systematic review. Thrombosis & Haemostasis. 2004;92(4):738-746. [pmid: 15467904].
45 Ranucci M, Isgro G, Soro G, et al. Efficacy and safety of recombinant activated factor vii in major surgical procedures: systematic review and meta-analysis of randomized clinical trials. Archives of Surgery. 2008;143(3):296-304. discussion 304. [pmid: 18347278].
46 Rose L. Recombinant factor VIIa: review of current “off license” indications and implications for practice. AACN Advanced Critical Care. 2007;18(2):141-148. [pmid: 17473542].
47 Stachnik JM, Gabay MP. Continuous infusion of coagulation factor products. Annals of Pharmacotherapy. 2002;36(5):882-891. [pmid: 11978168].
48 Tanos M, Dunning J. Is recombinant activated factor VII useful for intractable bleeding after cardiac surgery?. Interactive Cardiovascular & Thoracic Surgery. 2006;5(4):493-498. [pmid: 17670626].
49 Vincent J-L, Rossaint R, Riou B, et al. Recommendations on the use of recombinant activated factor VII as an adjunctive treatment for massive bleeding—a European perspective. Critical Care (London, England). 2006;10(4):R120.
50 von Heymann C, Jonas S, Spies C, et al. Recombinant activated factor VIIa for the treatment of bleeding in major abdominal surgery including vascular and urological surgery: a review and meta-analysis of published data. Critical Care (London, England). 2008;12(1):R14.
51 Warren O, Mandal K, Hadjianastassiou V, et al. Recombinant activated factor VII in cardiac surgery: a systematic review. Annals of Thoracic Surgery. 2007;83(2):707-714. [pmid: 17258029].
52 Warren OJ, Darzi AW, Athanasiou T. Recombinant activated factor VII in cardiac surgery—first, do no harm. Journal Of Cardiothoracic Surgery. 2007;2:50. [pmid: 18036233].
53 You H, Al-Shahi R. Haemostatic drug therapies for acute primary intracerebral haemorrhage. Cochrane Database of Systematic Reviews. 2006;3:CD005951.
54 Despotis G, Renna M, Eby C. Risks associated with bleeding and transfusion: rationale for the optimal management of bleeding after cardiac surgery. European Journal of Anaesthesiology. 2007;24(Suppl 40):15-36. [pmid: 16824241].
55 Diringer MN, Mayer SA, Brun NC, et al. Safety profile of recombinant factor VIIa in patients with intracerebral haemorrhage. European Journal of Neurology. 2006;13(Suppl. 2):9.
56 Ranucci M, Isgro G. Recombinant activated factor VII in cardiac surgery. European Journal of Anaesthesiology. 2007;24(Suppl 40):83-88.
57 Al-Shahi R, You H. Hemostatic Drug Therapies for Acute, Nontraumatic Intracerebral Hemorrhage. Stroke. 2006.
58 Argall J, Teece S, Mackway-Jones K. Factor VIIa for intractable blood loss in trauma. Emerg Med J. 2002;19:556-557. [pmid: 12421790].
59 Johansson PI. Off-label use of recombinant factor VIIa for treatment of haemorrhage: results from randomized clinical trials. Vox Sang. 2008;95(1):1-7. [pmid: 18435677].
60 Lam MS, Sims-McCallum RP. Recombinant factor VIIa in the treatment of non-hemophiliac bleeding. Ann Pharmacother. 2005;39(5):885-891. [pmid: 15784806].
61 Pape H-C. Recombinant factor viia for life-threatening hemorrhage in trauma patients: review of the literature. European Journal of Trauma. 2006;32(5):439-448.
62 Philipson MR, Parker PJ. Damage Control Orthopaedics. Trauma. 2007;9:245-254.
63 Squizzato A, Ageno W. Recombinant activated factor VII as a general haemostatic agent: evidence-based efficacy and safety. Curr Drug Saf. 2007;2(2):155-161. [pmid: 18690962].
64 US Department of Health and Human Services Code of Federal Regulation. Protection of Human Subjects: informed consent and waiver of informed consent requirements in certain emergency research: final rules 21 CFRPart 50.24 and 45 CFR Part 46.101. Fed Reg. 1996;61:5147-51528.
65 Food and Drug Administration. Code of federal regulations, title 21, part 50: protection of human subjects, exception from informed consent requirements for emergency research: 21 CFR section 50.24. Fed Reg. 1996;61:51528-51531.
66 Lewis RJ, Duber HC, Biros MH, et al. International resuscitation research, exception from informed consent, and the European Union Directive 2001/20/EC. Eur J Emerg Med. 2009;16(5):234-241. [pmid: 19433982].
67 Additional Protocol to the Convention on Human Rights and Biomedicine, concerning Biomedical Research. Council of Europe. Available at: http://www.w3.org/1999/xlink" xlink:href="http://www.conventions.coe.int/Treaty/Commun/QueVoulezVous.asp?NT=195&CM=8&DF=25/11/2009&CL=ENG (http://www.conventions.coe.int/Treaty/Commun/QueVoulezVous.asp?NT=195&CM=8&DF=25/11/2009&CL=ENG). Accessed: November 24, 2009.
68 Kozak LJ, DeFrances CJ, Hall MJ. National hospital discharge survey: 2004 annual summary with detailed diagnosis and procedure data. Vital Health Stat. 2006;13(162):1-209.
69 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
70 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-412. [pmid: 7823387].
71 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9128):609-613. [pmid: 9746022].
72 Kjaergard LL, Villumsen J, Gluud C. Reported methodologic quality and discrepancies between large and small randomized trials in meta-analyses. Ann Intern Med. 2001;135(11):982-989. [pmid: 11730399].
73 Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials. The CONSORT statement. JAMA. 1996;276(8):637-639. [pmid: 8773637].
74 Moher D, Schulz KF, Altman DG. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. Ann Intern Med. 2001;134(8):657-662. [pmid: 11304106].
75 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0 [Draft posted Oct. 2007]. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf. Accessed: November 24, 2009.
76 Owens DK, Lohr KN, Helfand M, et al. Grading the strength of a body of evidence when comparing medical interventions - AHRQ and the effective health care program. Journal of Clinical Epidemiology. 2009. (epub).
77 Sanderson S, Tatt ID, Higgins JP. Tools for assessing quality and susceptibility to bias in observational studies in epidemiology: a systematic review and annotated bibliography. Int J Epidemiol. 2007;36(3):666-676. [pmid: 17470488].
78 Deeks JJ, Dinnes J, D’Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173.
79 Vandenbroucke JP, von Elm E, Altman DG, et al. Strengthening the Reporting of Observational Studies in Epidemiology (STROBE): explanation and elaboration. PLoS Med. 2007;4(10):e297. [pmid: 17941715].
80 von Elm E, Altman DG, Egger M, et al. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. PLoS Med. 2007;4(10):e296. [pmid: 17941714].
81 Atkins D, Chang S, Gartleher G, et al. Assessing applicability when comparing medical interventions—AHRQ and the effective health care program. Journal of Clinical Epidemiology. 2009. in press.
82 Rucker G, Schwarzer G, Carpenter J, et al. Why add anything to nothing? The arcsine difference as a measure of treatment effect in meta-analysis with zero cells. Stat Med. 2009;28(5):721-738. [pmid: 19072749].
83 Fetouh F, Salah M, Sedeek K. 471974—the efficacy of low dose recombinant factor viia in the prophylaxis of bleeding during orthotropic liver transplantation. Canadian Journal of Anaesthesia. 2008;55(Suppl 1):471974.
84 Tong MZ, Chin-Yee I, Eckert K, et al. Efficacy and questionable safety of recombinant activated factor VII in intractable bleeding following cardiac surgery. Canadian Journal of Cardiology. 2007;23(Suppl C):291C.
85 Greaves P, Madhani M, Hallam S, et al. Off-license use of recombinant factor VIIa: a single centre experience. British Journal of Haematology. 2009;145(Suppl 1):34. [pmid: 19220284].
86 Mayer SA, Brun NC, Broderick J, et al. Safety and feasibility of recombinant factor VIIa for acute intracerebral hemorrhage. Stroke. 2005;36(1):74-79. [pmid: 15569871].
87 Mayer SA, Brun NC, Broderick J, et al. Recombinant activated factor VII for acute intracerebral hemorrhage: US phase IIA trial. Neurocritical Care. 2006;4(3):206-214. [pmid: 16757825].
88 Mayer SA, Brun NC, Begtrup K, et al. Efficacy and safety of recombinant activated factor VII for acute intracerebral hemorrhage. New England Journal of Medicine. 2008;358(20):2127-2137. [pmid: 18480205].
89 Ilyas C, Beyer GM, Dutton RP, et al. Recombinant factor VIIa for warfarin-associated intracranial bleeding. Journal of Clinical Anesthesia. 2008;20(4):276-279. [pmid: 18617125].
90 Pickard JD, Kirkpatrick PJ, Melsen T, et al. Potential role of NovoSeven in the prevention of rebleeding following aneurysmal subarachnoid haemorrhage. Blood Coagul Fibrinolysis. 2000;11(Suppl 1):S117-S120. [pmid: 10850576].
91 Brody DL, Aiyagari V, Shackleford AM, et al. Use of recombinant factor VIIa in patients with warfarin-associated intracranial hemorrhage. Neurocritical Care. 2005;2(3):263-267. [pmid: 16159073].
92 Hallevi H, Gonzales NR, Barreto AD, et al. The effect of activated factor VII for intracerebral hemorrhage beyond 3 hours versus within 3 hours. Stroke. 2008;39(2):473-475. [pmid: 18174476].
93 Sutherland CS, Hill MD, Kaufmann AM, et al. Recombinant factor VIIa plus surgery for intracerebral hemorrhage. Canadian Journal of Neurological Sciences. 2008;35(5):567-572. [pmid: 19235439].
94 Herbertson M, Kenet G. Applicability and safety of recombinant activated factor VII to control non-haemophilic haemorrhage: investigational experience in 265 children. Haemophilia. 2008;14(4):753-762. [pmid: 18445016].
95 Nussbaum ES, Janjua TM, Defillo A, et al. Perioperative use of recombinant factor VII to prevent intraoperative aneurysm rupture in high risk patients: a preliminary safety evaluation. Neurocritical Care. 2009;10(1):55-60. [pmid: 18818887].
96 Boffard KD, Riou B, Warren B, et al. Recombinant factor VIIa as adjunctive therapy for bleeding control in severely injured trauma patients: two parallel randomized, placebo-controlled, double-blind clinical trials. J Trauma. 2005;59(1):8-15. discussion 15–18. [pmid: 16096533].
97 Rizoli SB, Nascimento B Jr, Osman F, et al. Recombinant activated coagulation factor VII and bleeding trauma patients. Journal of Trauma-Injury Infection & Critical Care. 2006;61(6):1419-1425.
98 Spinella PC, Perkins JG, McLaughlin DF, et al. The effect of recombinant activated factor VII on mortality in combat-related casualties with severe trauma and massive transfusion. J Trauma. 2008;64(2):286-293. discussion 293–284. [pmid: 18301188].
99 Fox CJ, Mehta SG, Cox ED, et al. Effect of recombinant factor VIIa as an adjunctive therapy in damage control for wartime vascular injuries: a case control study. Journal of Trauma-Injury Infection & Critical Care. 2009;66(4 Suppl):S112-S119.
100 Dutton RP, McCunn M, Hyder M, et al. Factor VIIa for correction of traumatic coagulopathy. J Trauma. 2004;57(4):709-718. discussion 718–709. [pmid: 15514523].
101 Harrison TD, Laskosky J, Jazaeri O, et al. “Low-dose” recombinant activated factor VII results in less blood and blood product use in traumatic hemorrhage”. J Trauma. 2005;59(1):150-154. [pmid: 16096555].
102 Cameron P, Phillips L, Balogh Z, et al. The use of recombinant activated factor VII in trauma patients: Experience from the Australian and New Zealand haemostasis registry. Injury. 2007;38(9):1030-1038. [pmid: 17706654].
103 Felfernig M. Clinical experience with recombinant activated factor VII in a series of 45 trauma patients. J R Army Med Corps. 2007;153(1):32-39. [pmid: 17575875].
104 Martinowitz U, Michaelson M. The Israeli Multidisciplinary r FTF. Guidelines for the use of recombinant activated factor VII (rFVIIa) in uncontrolled bleeding: a report by the Israeli Multidisciplinary rFVIIa Task Force [see comment]. Journal of Thrombosis & Haemostasis. 2005;3(4):640-648. [pmid: 15842347].
105 Alten JA, Benner K, Green K, et al. Pediatric off-label use of recombinant factor VIIa. Pediatrics. 2009;123(3):1066-1072. [pmid: 19255041].
106 Narayan RK, Maas AI, Marshall LF, et al. Recombinant factor VIIA in traumatic intracerebral hemorrhage: results of a dose-escalation clinical trial. Neurosurgery. 2008;62(4):776-786. discussion 786–778. [pmid: 18496183].
107 Stein DM, Dutton RP, Kramer ME, et al. Recombinant factor VIIa: decreasing time to intervention in coagulopathic patients with severe traumatic brain injury. Journal of Trauma-Injury Infection & Critical Care. 2008;64(3):620-627. discussion 627–628.
108 Tawil I, Stein DM, Mirvis SE, et al. Posttraumatic cerebral infarction: incidence, outcome, and risk factors. Journal of Trauma-Injury Infection & Critical Care. 2008;64(4):849-853.
109 Bartal C, Freedman J, Bowman K, et al. Coagulopathic patients with traumatic intracranial bleeding: defining the role of recombinant factor VIIa. J Trauma. 2007;63(4):725-732. [pmid: 18089997].
110 Lodge JPA, Jonas S, Jones RM, et al. Efficacy and safety of repeated perioperative doses of recombinant factor VIIa in liver transplantation [see comment]. Liver Transplantation. 2005;11(8):973-979. [pmid: 16035095].
111 Planinsic RM, van der Meer J, Testa G, et al. Safety and efficacy of a single bolus administration of recombinant factor VIIa in liver transplantation due to chronic liver disease [see comment]. Liver Transplantation. 2005;11(8):895-900. [pmid: 16035081].
112 Pugliese F, Ruberto F, Summonti D, et al. Activated recombinant factor VII in orthotopic liver transplantation. Transplant Proc. 2007;39(6):1883-1885. [pmid: 17692642].
113 Liu JP, Chen T, Wang J, et al. Hemorrhagic features and the application of recombinant activated factor VII in liver transplantation. Journal of Clinical Rehabilitative Tissue Engineering Research. 2009;13(18):3580-3584.
114 Hendriks HG, Meijer K, de Wolf JT, et al. Reduced transfusion requirements by recombinant factor VIIa in orthotopic liver transplantation: a pilot study. Transplantation. 2001;71(3):402-405. [pmid: 11233901].
115 De Gasperi A, Baudo F, De Carlis L. Recombinant FVII in orthotopic liver transplantation (OLT): a preliminary single centre experience. Intensive Care Med. 2005;31:315-6. [pmid: 15592812].
116 Kalicinski P, Markiewicz M, Kaminski A, et al. Single pretransplant bolus of recombinant activated factor VII ameliorates influence of risk factors for blood loss during orthotopic liver transplantation. Pediatr Transplant. 2005;9(3):299-304. [pmid: 15910384].
117 Niemann CU, Behrends M, Quan D, et al. Recombinant factor VIIa reduces transfusion requirements in liver transplant patients with high MELD scores. Transfusion Medicine. 2006;16(2):93-100. [pmid: 16623915].
118 Diprose P, Herbertson MJ, O’Shaughnessy D, et al. Activated recombinant factor VII after cardiopulmonary bypass reduces allogeneic transfusion in complex non-coronary cardiac surgery: randomized double-blind placebo-controlled pilot study. Br J Anaesth. 2005;95(5):596-602. [pmid: 16183679].
119 Gill R, Herbertson M, Vuylsteke A, et al. Safety and efficacy of recombinant activated factor VII: a randomized placebo-controlled trial in the setting of bleeding after cardiac surgery. Circulation. 2009;120(1):21-27. [pmid: 19546387].
120 Karkouti K, Beattie WS, Wijeysundera DN, et al. Recombinant factor VIIa for intractable blood loss after cardiac surgery: a propensity score-matched case-control analysis. Transfusion. 2005;45(1):26-34. [pmid: 15647015].
121 Gelsomino S, Lorusso R, Romagnoli S, et al. Treatment of refractory bleeding after cardiac operations with low-dose recombinant activated factor VII (NovoSeven): a propensity score analysis. European Journal of Cardio-Thoracic Surgery. 2008;33(1):64-71. [pmid: 17996457].
122 Tritapepe L, De Santis V, Vitale D, et al. Recombinant activated factor VII for refractory bleeding after acute aortic dissection surgery: a propensity score analysis. Crit Care Med. 2007;35(7):1685-1690. [pmid: 17522585].
123 von Heymann C, Redlich U, Jain U, et al. Recombinant activated factor VII for refractory bleeding after cardiac surgery--a retrospective analysis of safety and efficacy. Critical Care Medicine. 2005;33(10):2241-2246. [pmid: 16215377].
124 Bowman LJ, Uber WE, Stroud MR, et al. Use of recombinant activated factor VII concentrate to control postoperative hemorrhage in complex cardiovascular surgery. Annals of Thoracic Surgery. 2008;85(5):1669-1676. discussion 1676–1667. [pmid: 18442563].
125 Trowbridge C, Stammers A, Klayman M, et al. Characteristics of uncontrolled hemorrhage in cardiac surgery. Journal of Extra-Corporeal Technology. 2008;40(2):89-93. [pmid: 18705543].
126 Filsoufi F, Castillo JG, Rahmanian PB, et al. Effective management of refractory postcardiotomy bleeding with the use of recombinant activated factor VII. Annals of Thoracic Surgery. 2006;82(5):1779-1783. [pmid: 17062247].
127 Gandhi MJ, Pierce RA, Zhang L, et al. Use of activated recombinant factor VII for severe coagulopathy post ventricular assist device or orthotopic heart transplant. Journal of Cardiothoracic Surgery. 2007;2:32. [pmid: 17617902].
128 Hyllner M, Houltz E, Jeppsson A. Recombinant activated factor VII in the management of life-threatening bleeding in cardiac surgery. European Journal of Cardio-Thoracic Surgery. 2005;28(2):254-258. [pmid: 15935687].
129 McCall P, Story DA, Karapillai D. Audit of factor VIIa for bleeding resistant to conventional therapy following complex cardiac surgery. Canadian Journal of Anaesthesia. 2006;53(9):926-933. [pmid: 16960271].
130 Raivio P, Suojaranta-Ylinen R, Kuitunen AH. Recombinant factor VIIa in the treatment of postoperative hemorrhage after cardiac surgery [see comment]. Annals of Thoracic Surgery. 2005;80(1):66-71. [pmid: 15975342].
131 Aggarwal A, Malkovska V, Catlett JP, et al. Recombinant activated factor VII (rFVIIa) as salvage treatment for intractable hemorrhage. Thromb J. 2004;2(1):9. [pmid: 15530167].
132 Karkouti K, Beattie WS, Arellano R, et al. Comprehensive Canadian review of the off-label use of recombinant activated factor VII in cardiac surgery. Circulation. 2008;118(4):331-338. [pmid: 18606914].
133 Dunkley S, Phillips L, McCall P, et al. Recombinant activated factor VII in cardiac surgery: experience from the Australian and New Zealand Haemostasis Registry. Ann Thorac Surg. 2008;85(3):836-844. [pmid: 18291152].
134 Bruckner BA, DiBardino DJ, Ning Q, et al. High incidence of thromboembolic events in left ventricular assist device patients treated with recombinant activated factor VII. Journal of Heart & Lung Transplantation. 2009;28(8):785-790. [pmid: 19632574].
135 Masud F, Bostan F, Chi E, et al. Recombinant factor VIIa treatment of severe bleeding in cardiac surgery patients: a retrospective analysis of dosing, efficacy, and safety outcomes. Journal of Cardiothoracic & Vascular Anesthesia. 2009;23(1):28-33. [pmid: 18948033].
136 Hsia CC, Zurawska JH, Tong MZ, et al. Recombinant activated factor VII in the treatment of non-haemophilia patients: physician under-reporting of thromboembolic adverse events. Transfusion Medicine. 2009;19(1):43-49. [pmid: 19302454].
137 Ekert H, Brizard C, Eyers R, et al. Elective administration in infants of low-dose recombinant activated factor VII (rFVIIa) in cardiopulmonary bypass surgery for congenital heart disease does not shorten time to chest closure or reduce blood loss and need for transfusions: a randomized, double-blind, parallel group, placebo-controlled study of rFVIIa and standard haemostatic replacement therapy versus standard haemostatic replacement therapy. Blood Coagulation & Fibrinolysis. 2006;17(5):389-395. [pmid: 16788315].
138 Agarwal HS, Bennett JE, Churchwell KB, et al. Recombinant factor seven therapy for postoperative bleeding in neonatal and pediatric cardiac surgery. Ann Thorac Surg. 2007;84(1):161-168. [pmid: 17588404].
139 Tobias JD, Simsic JM, Weinstein S, et al. Recombinant factor VIIa to control excessive bleeding following surgery for congenital heart disease in pediatric patients. Journal of Intensive Care Medicine. 2004;19(5):270-273. [pmid: 15358945].
140 Niles SD, Burkhart HM, Duffey DA, et al. Use of recombinant factor VIIa (NovoSeven) in pediatric cardiac surgery. Journal of Extra-Corporeal Technology. 2008;40(4):241-248. [pmid: 19192753].
141 Friederich PW, Henny CP, Messelink EJ, et al. Effect of recombinant activated factor VII on perioperative blood loss in patients undergoing retropubic prostatectomy: a double-blind placebo-controlled randomised trial [see comment] [erratum appears in Lancet 2003 Mar 29;361(9363):1138]. Lancet. 2003;361(9353):201-205. [pmid: 12547542].
142 Jeffers L, Chalasani N, Balart L, et al. Safety and efficacy of recombinant factor VIIa in patients with liver disease undergoing laparoscopic liver biopsy. Gastroenterology. 2002;123(1):118-126. [pmid: 12105840].
143 Bosch J, Thabut D, Bendtsen F, et al. Recombinant factor VIIa for upper gastrointestinal bleeding in patients with cirrhosis: a randomized, double-blind trial. Gastroenterology. 2004;127(4):1123-1130. [pmid: 15480990].
144 Shao YF, Yang JM, Chau GY, et al. Safety and hemostatic effect of recombinant activated factor VII in cirrhotic patients undergoing partial hepatectomy: a multicenter, randomized, double-blind, placebo-controlled trial. Am J Surg. 2006;191(2):245-249. [pmid: 16442954].
145 Bosch J, Thabut D, Albillos A, et al. Recombinant factor VIIa for variceal bleeding in patients with advanced cirrhosis: A randomized, controlled trial. Hepatology. 2008;47(5):1604-1614. [pmid: 18393319].
146 Shami VM, Caldwell SH, Hespenheide EE, et al. Recombinant activated factor VII for coagulopathy in fulminant hepatic failure compared with conventional therapy. Liver Transplantation. 2003;9(2):138-143. [pmid: 12548507].
147 Ahonen J, Jokela R, Korttila K. An open non-randomized study of recombinant activated factor VII in major postpartum haemorrhage. Acta Anaesthesiologica Scandinavica. 2007;51(7):929-936. [pmid: 17488316].
148 Hossain N, Shamsi T, Haider S, et al. Use of recombinant activated factor VII for massive postpartum hemorrhage. Acta Obstet Gynecol Scand. 2007:1-7.
149 McMorrow RCN, Ryan SM, Blunnie WP, et al. Use of recombinant factor VIIa in massive post-partum haemorrhage. European Journal of Anaesthesiology. 2008;25(4):293-298. [pmid: 18177539].
150 Chuansumrit A, Wangruangsatid S, Lektrakul Y, et al. Control of bleeding in children with Dengue hemorrhagic fever using recombinant activated factor VII: a randomized, double-blind, placebo-controlled study. Blood Coagulation & Fibrinolysis. 2005;16(8):549-555. [pmid: 16269927].
151 Pihusch M, Bacigalupo A, Szer J, et al. Recombinant activated factor VII in treatment of bleeding complications following hematopoietic stem cell transplantation [see comment]. Journal of Thrombosis & Haemostasis. 2005;3(9):1935-1944. [pmid: 16102099].
152 Gupta S, Jain A, Warneke CL, et al. Outcome of alveolar hemorrhage in hematopoietic stem cell transplant recipients. Bone Marrow Transplant. 2007;40(1):71-78. [pmid: 17483846].
153 Lodge JP, Jonas S, Oussoultzoglou E, et al. Recombinant coagulation factor VIIa in major liver resection: a randomized, placebo-controlled, double-blind clinical trial. Anesthesiology. 2005;102(2):269-275. [pmid: 15681939].
154 Raobaikady R, Redman J, Ball JAS, et al. Use of activated recombinant coagulation factor VII in patients undergoing reconstruction surgery for traumatic fracture of pelvis or pelvis and acetabulum: a double-blind, randomized, placebo-controlled trial [see comment]. British Journal of Anaesthesia. 2005;94(5):586-591. [pmid: 15734783].
155 Johansson PI, Eriksen K, Nielsen SL, et al. Recombinant FVIIa decreases perioperative blood transfusion requirement in burn patients undergoing excision and skin grafting--results of a single centre pilot study. Burns. 2007;33(4):435-440. [pmid: 17382476].
156 Sachs B, Delacy D, Green J, et al. Recombinant activated factor VII in spinal surgery: a multicenter, randomized, double-blind, placebo-controlled, dose-escalation trial. Spine. 2007;32(21):2285-2293. [pmid: 17906567].
157 Roitberg B, Emechebe-Kennedy O, Amin-Hanjani S, et al. Human recombinant factor VII for emergency reversal of coagulopathy in neurosurgical patients: a retrospective comparative study. Neurosurgery. 2005;57(5):832-836. discussion 832–836. [pmid: 16284552].
158 Kolban M, Balachowska-Kosciolek I, Chmielnicki M. Recombinant coagulation factor VIIa--a novel haemostatic agent in scoliosis surgery?. Eur Spine J. 2006;15(6):944-952. [pmid: 16133083].
159 Broderick JP, Brott TG, Duldner JE, et al. Volume of intracerebral hemorrhage. A powerful and easy-to-use predictor of 30-day mortality. Stroke. 1993;24(7):987-993. [pmid: 8322400].
160 Jeng JS, Huang SJ, Tang SC, et al. Predictors of survival and functional outcome in acute stroke patients admitted to the stroke intensive care unit. J Neurol Sci. 2008;270(1–2):60-66. [pmid: 18299138].
161 Mayer SA. Ultra-early hemostatic therapy for intracerebral hemorrhage. Stroke. 2003;34(1):224-229. [pmid: 12511778].
162 Broderick J, Connolly S, Feldmann E, et al. Guidelines for the management of spontaneous intracerebral hemorrhage in adults: 2007 update: a guideline from the American Heart Association/American Stroke Association Stroke Council, High Blood Pressure Research Council, and the Quality of Care and Outcomes in Research Interdisciplinary Working Group. Stroke. 2007;38(6):2001-2023. [pmid: 17478736].
163 Ohwaki K, Yano E, Nagashima H, et al. Blood pressure management in acute intracerebral hemorrhage: relationship between elevated blood pressure and hematoma enlargement. Stroke. 2004;35(6):1364-1367. [pmid: 15118169].
164 Qureshi AI, Mohammad YM, Yahia AM, et al. A prospective multicenter study to evaluate the feasibility and safety of aggressive antihypertensive treatment in patients with acute intracerebral hemorrhage. J Intensive Care Med. 2005;20(1):34-42. [pmid: 15665258].
165 Anderson CS, Huang Y, Wang JG, et al. Intensive blood pressure reduction in acute cerebral haemorrhage trial (INTERACT): a randomised pilot trial. Lancet Neurol. 2008;7(5):391-399. [pmid: 18396107].
166 Novo Nordisk. Available at: http://www.novonordisk-trials.com/WebSite/search/trial-result-details.aspx?id=1414. Accessed: May 22, 2009.
167 Brott T, Broderick J, Kothari R, et al. Early hemorrhage growth in patients with intracerebral hemorrhage. Stroke. 1997;28(1):1-5. [pmid: 8996478].
168 Sauaia A, Moore FA, Moore EE, et al. Epidemiology of trauma deaths: a reassessment. J Trauma. 1995;38(2):185-193. [pmid: 7869433].
169 Brohi K. Diagnosis and management of coagulopathy after major trauma. Br J Surg. 2009;96(9):963-964. [pmid: 19672928].
170 Hess JR, Brohi K, Dutton RP, et al. The coagulopathy of trauma: a review of mechanisms. J Trauma. 2008;65(4):748-754. [pmid: 18849786].
171 Brohi K, Cohen MJ, Ganter MT, et al. Acute coagulopathy of trauma: hypoperfusion induces systemic anticoagulation and hyperfibrinolysis. J Trauma. 2008;64(5):1211-1217. discussion 1217. [pmid: 18469643].
172 Brohi K, Singh J, Heron M, et al. Acute traumatic coagulopathy. J Trauma. 2003;54(6):1127-1130. [pmid: 12813333].
173 Moore FA, Moore EE, Sauaia A. Blood transfusion. An independent risk factor for postinjury multiple organ failure. Arch Surg. 1997;132(6):620-624. discussion 624–625. [pmid: 9197854].
174 Claridge JA, Sawyer RG, Schulman AM, et al. Blood transfusions correlate with infections in trauma patients in a dose-dependent manner. Am Surg. 2002;68(7):566-572. [pmid: 12132734].
175 Croce MA, Tolley EA, Claridge JA, et al. Transfusions result in pulmonary morbidity and death after a moderate degree of injury. J Trauma. 2005;59(1):19-23. discussion 23–14. [pmid: 16096534].
176 Fraga GP, Bansal V, Coimbra R. Transfusion of blood products in trauma: an update. J Emerg Med. 2009.
177 Riskin DJ, Tsai TC, Riskin L, et al. Massive transfusion protocols: the role of aggressive resuscitation versus product ratio in mortality reduction. J Am Coll Surg. 2009;209(2):198-205. [pmid: 19632596].
178 Evaluation of Recombinant Factor VIIa in Patients With Severe Bleeding Due to Trauma. Clinicaltrials.gov identifier: NCT00323570.
179 Massive blood loss: does rFVIIa help?. Paper presented at: International symposium of intensive care and medicine; March 24–27, 2009. Brussels, Belgium. Available at: http://www.intensive.org/newsletter/fullday2.html. Accessed November 5, 2009.
180 Dutton R, Hauser C, Boffard K, et al. Scientific and logistical challenges in designing the CONTROL trial: recombinant factor VIIa in severe trauma patients with refractory bleeding. Clin Trials. 2009;6(5):467-479. [pmid: 19737846].
181 Nascimento B Jr, Tien H, Pinto R, et al. Dosage of Factor VIIa (rFVIIa) and mortality in bleeding trauma patients. Journal of Trauma Injury Infection and Critical Care. 2008;64(2):558.
182 Perkins JG, Schreiber MA, Wade CE, et al. Early versus late recombinant factor VIIa in combat trauma patients requiring massive transfusion. Journal of Trauma-Injury Infection & Critical Care. 2007;62(5):1095-1099. discussion 1099–1101.
183 Shackford SR, Mackersie RC, Holbrook TL, et al. The epidemiology of traumatic death. A population-based analysis. Arch Surg. 1993;128(5):571-575. [pmid: 8489391].
184 Lannoo E, Van Rietvelde F, Colardyn F, et al. Early predictors of mortality and morbidity after severe closed head injury. J Neurotrauma. 2000;17(5):403-414. [pmid: 10833059].
185 Stein SC, Smith DH. Coagulopathy in traumatic brain injury. Neurocritical Care. 2004;1(4):479-488. [pmid: 16174954].
186 Chieregato A, Fainardi E, Morselli-Labate AM, et al. Factors associated with neurological outcome and lesion progression in traumatic subarachnoid hemorrhage patients. Neurosurgery. 2005;56(4):671-680. discussion 671–680. [pmid: 15792505].
187 Chang EF, Meeker M, Holland MC. Acute traumatic intraparenchymal hemorrhage: risk factors for progression in the early post-injury period. Neurosurgery. 2006;58(4):647-656. discussion 647–656. [pmid: 16575328].
188 Etemadrezaie H, Baharvahdat H, Shariati Z, et al. The effect of fresh frozen plasma in severe closed head injury. Clin Neurol Neurosurg. 2007;109(2):166-171. [pmid: 17029771].
189 Stein DM, Dutton RP, Kramer ME, et al. Reversal of coagulopathy in critically ill patients with traumatic brain injury: recombinant factor VIIa is more cost-effective than plasma. Journal of Trauma-Injury Infection & Critical Care. 2009;66(1):63-72. discussion 73–65.
190 Mirvis SE, Wolf AL, Numaguchi Y, et al. Posttraumatic cerebral infarction diagnosed by CT: prevalence, origin, and outcome. AJNR Am J Neuroradiol. 1990;11(2):355-360. [pmid: 2107719].
191 Ozier Y, Tsou MY. Changing trends in transfusion practice in liver transplantation. Curr Opin Organ Transplant. 2008;13(3):304-309. [pmid: 18685322].
192 Palomo Sanchez JC, Jimenez C, Moreno Gonzalez E, et al. Effects of intraoperative blood transfusion on postoperative complications and survival after orthotopic liver transplantation. Hepatogastroenterology. 1998;45(22):1026-1033. [pmid: 9756002].
193 Ramos E, Dalmau A, Sabate A, et al. Intraoperative red blood cell transfusion in liver transplantation: influence on patient outcome, prediction of requirements, and measures to reduce them. Liver Transpl. 2003;9(12):1320-1327. [pmid: 14625833].
194 Cacciarelli TV, Keeffe EB, Moore DH, et al. Effect of intraoperative blood transfusion on patient outcome in hepatic transplantation. Arch Surg. 1999;134(1):25-29. [pmid: 9927126].
195 Sanchez-Bueno F, Hernandez Q, Ramirez P, et al. Vascular complications in a series of 300 orthotopic liver transplants. Transplant Proc. 1999;31(6):2409-2410. [pmid: 10500645].
196 de Boer MT, Molenaar IQ, Hendriks HG, et al. Minimizing blood loss in liver transplantation: progress through research and evolution of techniques. Dig Surg. 2005;22(4):265-275. [pmid: 16174983].
197 Spahn DR, Casutt M. Eliminating blood transfusions: new aspects and perspectives. Anesthesiology. 2000;93(1):242-255. [pmid: 10861168].
198 Detry O, Deroover A, Delwaide J, et al. Avoiding blood products during liver transplantation. Transplant Proc. 2005;37(6):2869-2870. [pmid: 16182837].
199 Ramos HC, Todo S, Kang Y, et al. Liver transplantation without the use of blood products. Arch Surg. 1994;129(5):528-532. discussion 532–523. [pmid: 8185476].
200 Jabbour N, Gagandeep S, Mateo R, et al. Transfusion free surgery: single institution experience of 27 consecutive liver transplants in Jehovah’s Witnesses. J Am Coll Surg. 2005;201(3):412-417. [pmid: 16125075].
201 Jeffrey GP, McCall J, Gane E, et al. Liver transplantation in Jehovah’s Witness patients in Australasia. Med J Aust. 2007;187(3):188-189. [pmid: 17680750].
202 Diprose P, Herbertson MJ, O’Shaughnessy D, et al. Reducing allogeneic transfusion in cardiac surgery: a randomized double-blind placebo-controlled trial of antifibrinolytic therapies used in addition to intra-operative cell salvage. Br J Anaesth. 2005;94(3):271-278. [pmid: 15591329].
203 Woodman RC, Harker LA. Bleeding complications associated with cardiopulmonary bypass. Blood. 1990;76(9):1680-1697. [pmid: 2224118].
204 McGill N, O’Shaughnessy D, Pickering R, et al. Mechanical methods of reducing blood transfusion in cardiac surgery: randomised controlled trial. BMJ. 2002;324(7349):1299. [pmid: 12039820].
205 Moulton MJ, Creswell LL, Mackey ME, et al. Reexploration for bleeding is a risk factor for adverse outcomes after cardiac operations. J Thorac Cardiovasc Surg. 1996;111(5):1037-1046. [pmid: 8622301].
206 Dacey LJ, Munoz JJ, Baribeau YR, et al. Reexploration for hemorrhage following coronary artery bypass grafting: incidence and risk factors. Northern New England Cardiovascular Disease Study Group. Arch Surg. 1998;133(4):442-447. [pmid: 9565127].
207 Nuttall GA, Oliver WC, Ereth MH, et al. Comparison of blood-conservation strategies in cardiac surgery patients at high risk for bleeding. Anesthesiology. 2000;92(3):674-682. [pmid: 10719945].
208 Keogh B, Kinsman R. Fifth National Adult Cardiac Surgical Database Report 2003: improving outcomes for patients. Reading, Massachusetts. Society of Cardiothoracic Surgeons of Great Britain and Ireland, Dendrite Clinical Systems Ltd. 2004.
209 Reeves BC, Murphy GJ. Increased mortality, morbidity, and cost associated with red blood cell transfusion after cardiac surgery. Curr Opin Cardiol. 2008;23(6):607-612. [pmid: 18830077].
210 Murphy GJ, Angelini GD. Indications for blood transfusion in cardiac surgery. Ann Thorac Surg. 2006;82(6):2323-2334. [pmid: 17126171].
211 Ma B, Wang ZN, Zhang BR, et al. [Effect of recombinant activated factor VII a on early recovery of patients undergoing cardiac valve replacement under cardiopulmonary bypass: A randomized double-blind placebo-controlled trial]. Academic Journal of Second Military Medical University. 2006;27(10):1110-1113.
212 Romagnoli S, Bevilacqua S, Gelsomino S, et al. Small-dose recombinant activated factor VII (NovoSeven) in cardiac surgery. Anesth Analg. 2006;102(5):1320-1326. [pmid: 16632803].
213 Use of Activated Recombinant Human Factor VII in Cardiac Surgery. ClinicalTrials. Gov identifier NCT00154427.
214 Novo Nordisk. Synopsis: A multi-centre, randomised, double-blind, placebo-controlled, dose escalation trial on safety and efficacy of activated recombinant factor VII (rFVIIa/NovoSeven^®^) in the treatment of post-operative bleeding in patients following cardiac surgery requiring cardiopulmonary bypass. Available at: http://www.novonordisk-trials.com/website/pdf/registry/bin_20081120-011014-384.pdf. Accessed November 13, 2009.
215 Karkouti K, Yau TM, Riazi S, et al. Determinants of complications with recombinant factor VIIa for refractory blood loss in cardiac surgery. Canadian Journal of Anaesthesia. 2006;53(8):802-809. [pmid: 16873347].
216 Arnold DM, Fergusson DA, Chan AK, et al. Avoiding transfusions in children undergoing cardiac surgery: a meta-analysis of randomized trials of aprotinin. Anesth Analg. 2006;102(3):731-737. [pmid: 16492820].
217 Carrel TP, Schwanda M, Vogt PR, et al. Aprotinin in pediatric cardiac operations: a benefit in complex malformations and with high-dose regimen only. Ann Thorac Surg. 1998;66(1):153-158. [pmid: 9692456].
218 Oliver WC Jr, Santrach PJ, Danielson GK, et al. Desmopressin does not reduce bleeding and transfusion requirements in congenital heart operations. Ann Thorac Surg. 2000;70(6):1923-1930. [pmid: 11156096].
219 Reynolds LM, Nicolson SC, Jobes DR, et al. Desmopressin does not decrease bleeding after cardiac operation in young children. J Thorac Cardiovasc Surg. 1993;106(6):954-958. [pmid: 8246577].
220 Seear MD, Wadsworth LD, Rogers PC, et al. The effect of desmopressin acetate (DDAVP) on postoperative blood loss after cardiac operations in children. J Thorac Cardiovasc Surg. 1989;98(2):217-219. [pmid: 2666759].
221 Rastan AJ, Lachmann N, Walther T, et al. Autopsy findings in patients on postcardiotomy extracorporeal membrane oxygenation (ECMO). Int J Artif Organs. 2006;29(12):1121-1131. [pmid: 17219352].
222 Gruenwald CE, McCrindle BW, Crawford-Lean L, et al. Reconstituted fresh whole blood improves clinical outcomes compared with stored component blood therapy for neonates undergoing cardiopulmonary bypass for cardiac surgery: a randomized controlled trial. J Thorac Cardiovasc Surg. 2008;136(6):1442-1449. [pmid: 19114187].
223 Mou SS, Giroir BP, Molitor-Kirsch EA, et al. Fresh whole blood versus reconstituted blood for pump priming in heart surgery in infants. N Engl J Med. 2004;351(16):1635-1644. [pmid: 15483282].
224 Szekely A, et al. Risks and predictors of blood transfusion in pediatric patients undergoing open heart operations. Ann Thor Surg. 2009;87:187-197.
225 Guillonneau B, Cathelineau X, Doublet JD, et al. Laparoscopic radical prostatectomy: assessment after 550 procedures. Crit Rev Oncol Hematol. 2002;43(2):123-133. [pmid: 12191734].
226 Volk T, von Heymann C, Kox WJ. Recombinant activated factor VII and perioperative blood loss [comment]. Lancet. 2003;361:9370-1745. author reply 1745–1746.
227 Turk I, Deger S, Winkelmann B, et al. Radical prostatectomy in clinically localized prostate carcinoma. Pro laparoscopic approach. Urologe A. 2002;41(1):48-54. [pmid: 11963775].
228 Thomas GO, Dutton RP, Hemlock B, et al. Thromboembolic complications associated with factor VIIa administration. J Trauma. 2007;62(3):564-569. [pmid: 17414329].
229 Annual Scientific Meeting of the Trauma-Association-of-Canada, Whistler, CANADA, April 03 -05, 2008. Journal of Trauma Injury Infection and Critical Care. 2008;64(2):544-559.
230 Hsia CC, Chin-Yee IH, McAlister VC, et al. Use of recombinant activated factor VII in patients without hemophilia: a meta-analysis of randomized control trials. Annals of Surgery. 2008;248(1):61-68. [pmid: 18580208].
231 Pohar SL, Tsakonas E, Murphy G, et al. Recombinant activated factor VII in treatment of hemorrhage unrelated to hemophilia: a systematic review and economic evaluation [Technology report number 118]. Ottawa. Canadian Agency for Drugs and Technologies in Health. 2009.
232 Al-Shahi Salman R. Haemostatic drug therapies for acute spontaneous intracerebral haemorrhage. Cochrane Database Syst Rev. 2009(4):CD005951.
233 Duchesne JC, Mathew KA, Marr AB, et al. Current evidence based guidelines for factor VIIa use in trauma: the good, the bad, and the ugly. Am Surg. 2008;74(12):1159-1165. [pmid: 19097529].
234 Patanwala AE. Factor VIIa (recombinant) for acute traumatic hemorrhage. Am J Health Syst Pharm. 2008;65(17):1616-1623. [pmid: 18714107].
235 Zangrillo A, Mizzi A, Biondi-Zoccai G, et al. Recombinant activated factor VII in cardiac surgery: a meta-analysis. J Cardiothorac Vasc Anesth. 2009;23(1):34-40. [pmid: 19081268].
236 Dunning J, Versteegh M, Fabbri A, et al. Guideline on antiplatelet and anticoagulation management in cardiac surgery. Eur J Cardiothorac Surg. 2008;34(1):73-92. [pmid: 18375137].
237 O’Connell KA, Wood JJ, Wise RP, et al. Thromboembolic adverse events after use of recombinant human coagulation factor VIIa. Jama. 2006;295(3):293-298. [pmid: 16418464].
238 Iorio A. Latrogenic causes of an ICH: OAT therapy. European Journal of Anaesthesiology Suppl. 2008;42:8-11.
239 Mayer SA, Brun NC, Begtrup K, et al. Efficacy and safety of recombinant activated factor VII for acute intracerebral hemorrhage. The New England Journal of Medicine. 2008;358(20):2127-2137. [pmid: 18480205].
240 Ashrani AA, Gabriel DA, Gajewski JL, et al. Pilot study to test the efficacy and safety of activated recombinant factor VII (NovoSeven) in the treatment of refractory hemorrhagic cystitis following high-dose chemotherapy. Bone Marrow Transplantation. 2006;38(12):825-828. [pmid: 17133240].
241 Gabriel DA, Skolnick BE, Leese P, et al. Ex-vivo assessments in the evaluation of dose response to recombinant factor VIIa when administered for bleeding following punch biopsies in healthy volunteers. Blood. 2005;106(11, Part 2):94B.
242 Gabriel DA, Skolnick BE, Seremetis S, et al. Effect of recombinant activated factor VII (rFVIIa) on platelet and clotting systems in healthy volunteers. Blood. 2005;106(11, Part 2):93B.
243 Gabriel DA, Skolnick BE, Rojkjaer LP, et al. Variations in ex-vivo assessments of hemostasis. Blood. 2005;106:11. Abstract 4052.
244 Bosch J, Thabut D, Albillos A, et al. Recombinant factor VIIa-(Rfviia) for active variceal bleeding in patients with advanced cirrhosis: A multi-center randornised double-blind placebo-controlled trial. Gastroenterology. 2007;132(4 Suppl. 2):A728.