# Introduction

This report evaluates the level of evidence currently available to support the effectiveness and safety of using recombinant activated coagulation factor VII (rFVIIa) for clinical indications beyond those approved by the Food and Drug Administration (FDA). rFVIIa is approved for a variety of uses in hemophilia patients who have developed antibody inhibitors that compromise the use of standard factor replacement. Use of this costly biologic product has expanded beyond these hemophilia-related indications to encompass a range of off-label uses that differ from the drug’s FDA approved label. The purpose of this report is two-fold: (1) To profile the full range of clinical indications for which rFVIIa is being used and the types of studies available to evaluate these uses, and (2) To provide a comparative effectiveness review of rFVIIa versus usual care for several clinical indications: intracranial hemorrhage, massive bleeding secondary to trauma, and the selected surgical procedures of cardiac surgery, liver transplantation, and prostatectomy.

The spectrum of rFVIIa use is broad, involving a range of surgical and medical specialties. In the first part of this report, we provide a full description of the evolution of rFVIIa’s off-label in-hospital uses through 2008 based on both a literature review and analysis of national hospital data. While a comparative effectiveness review for every off-label use of rFVIIa is beyond the scope of this report, in the first part of this report (Key Question 1) we document the randomized controlled trials and comparative observational studies of rFVIIa for the full spectrum of clinical conditions to which it has been applied. These analyses identify what other clinical indications beyond those selected for comparative effectiveness review might also warrant focused attention in the future.

In the second part of this report (Key Questions 2-4), we present a comparative effectiveness review of the benefits and harms of rFVIIa versus usual care for ***the selected clinical indications of intracranial hemorrhage, bleeding secondary to trauma, cardiac surgery, liver transplantation, and prostatectomy. These off-label indications have been prominent in debates about the effectiveness and safety of rFVIIa, including potentially ambiguous benefits and the occurrence of infrequent but catastrophic adverse events. We compare rFVIIa to usual care because there is currently no notable competing product for the clinical indications assessed. We focus on randomized clinical trials (RCTs) as the primary source of information on rFVIIa’s potential benefits, but also rely on a range of observational studies to more fully characterize its potential for harm.1 When adequate information exists, we perform meta-analyses. For each indication, we also provide an overall assessment of the balance of rFVIIa benefits and harms. Because benefits and harms may vary by subpopulation or medication dose, we also evaluate outcomes according to these variables, when possible. Finally, we suggest critical gaps in evidence that might be usefully filled by future clinical research.

## Organization of Report

This report begins in the Introduction with a Background on Off-label Medication Use, with a particular focus on its relevant advantages and disadvantages. We provide an Introduction to rFVIIa, including its biology, known patterns of use, regulatory history, and current uncertainty regarding its safety and benefits. We provide a summary of Areas of Anticipated Challenge that we recognized as we undertook the project.

In the Methods, we describe our approach to analyzing rFVIIa off-label use, including the Analytic Framework, [underlined: Methods to Describe the Spectrum of rFVIIa Off-label Use] and [underlined: Methods of rFVIIa Comparative Effectiveness Review] for intracranial hemorrhage, traumatic bleeding, and the three selected surgical procedures.

Our Results on rFVIIa Off-label Use provide a description of the evolution of rFVIIa off-label use, as well as the extent to which studies exist that evaluate this use at the level of individual indications. The rFVIIa Comparative Effectiveness Results presents our findings in detail, both at the level of individual research studies and in aggregate (as appropriate).

Our Discussion interprets our comparative effectiveness results in light of prior systematic reviews and current trends of rFVIIa use. Where adequate evidence exists, we provide an overall assessment of the value of rFVIIa for each prominent off-label use. Where it does not exist, we identify critical gaps in information recommended as targets for future study.

## Background on Off-Label Medication Use

### Defining Off-Label Drug Use

Off-label use refers to any use of a medication (or medical device) that differs from the product labeling approved and required by the United States Food and Drug Administration (FDA). The FDA drug approval process requires randomized clinical trials that demonstrate efficacy for specific indications prior to marketing. Once approval is given, however, the FDA does not regulate whether drugs are prescribed for “off-label” indications. Although the extent of evaluation and evidence supporting the efficacy and safety of off-label use may vary tremendously by drug, in all but rare many instances it falls short of the extensive research and scientific scrutiny that accompanies initial FDA review.2 In cases where drugs are being used infrequently, this uncertainty may be acceptable. On the other hand, concern increases when larger populations are served, when off-label indications become more clinically or biologically distinct from the approved indications, when the drug is costly, when the safety and response to therapy in anecdotal cases may be over-generalized, and when a drug is used in a different clinical setting.

### Regulatory Context

The FDA’s review of a New Drug Application (NDA) evaluates a product’s use for specific indications prior to allowing the product to be marketed. Each distinct indication requires a series of RCTs that demonstrate safety and efficacy for that condition. The FDA focuses on controlling market entry. After approval, physicians are free to use the medications as they wish, and the FDA is specifically enjoined from influencing the practice of medicine. While supplemental NDAs are an available mechanism for adding indications to an existing approval, manufacturers may not seek them, particularly if the indications are difficult or costly to evaluate. There are a great variety of ways in which drug use may differ from FDA labeling. Off-label use can extend the clinical logic from the approved indication to others, such as milder forms of the approved indication (e.g., using antidepressants for dysthymia) or clinically related conditions (e.g., applying asthma treatments to COPD). In addition, drugs may be used for patient subpopulations not approved by the FDA (e.g., children and adolescents)3 or used as monotherapy when approved only as an adjunct therapy (and vice versa).4

### Advantages and Disadvantages

There is a range of conflicting perspectives on off-label use. Payers question the need to pay for unproven products, physicians want autonomy to meet individual patient needs, and the pharmaceutical industry may identify additional indications for which they could potentially seek FDA approval. For their part, consumers expect drugs that are safe, effective, evidence-based, and affordable, but are often willing to lower their standards in the case of new therapies.5

Off-label use has a number of advantages, including facilitating innovation in clinical practice, offering clinical solutions when approved treatments fail, offering earlier access to potentially valuable medications, allowing adoption of new practices based on emerging evidence, providing the only available treatments for orphan conditions, and, occasionally, providing less expensive therapy.5 rFVIIa might share many of these attributes to the extent that its use proves safe and efficacious for its off-label indications.

On the other hand, off-label use carries important disadvantages, not the least of which is the way it may undercut public and physician expectations about the full evaluation of drug safety and efficacy.5 Off-label use can also increase health care costs, especially when newer, more expensive drugs are used. It may undermine incentives for the pharmaceutical industry to perform the additional rigorous clinical studies needed for FDA approval of new indications. Finally, off-label use may indirectly discourage evidence-based practice if it reduces the expectation that available evidence guides clinical practice.6

### Unique Aspects of Biologics and Off-Label Use

There are several special issues when biologics, such as rFVIIa, are used off-label. The high cost of development leads to an even higher product cost—for example, in the case of rFVIIa, up to $10,300 for a single 90 μg/kg dose in a 70 kg patient,7 with total in -hospital U.S. sales of rFVIIa in 2007 estimated to have been $138.5 million.8 The injectable form of most biologics limits the potentially available population to severe conditions not treatable with oral medications. While these products are often deployed initially in life threatening situations on a limited number of patients, their application is often expanded into milder forms of disease or into distinctly different conditions, which appears to be the case for rFVIIa.

rFVIIa occupies a unique niche in that its approved indication is relatively rare. The U.S. prevalence of Hemophilia A and Hemophilia B (conditions in which individuals have deficiencies in clotting factors VIII and IX, respectively): 1:10,000 and 1:25,000, respectively.9 Of these individuals, relatively few ever require rFVIIa for treatment as a result of developing antibody inhibitors to the exogenous coagulation factors given to replace the deficient factor. Inhibitors to factor VIII develop in 0.45–1.5 patients with Hemophilia A per 10,000 patient-years, with population rates of 0.3 percent in patients with mild Hemophilia A and 30 percent in those with severe forms.10 In contrast, development of a Factor IX inhibitor in Hemophlia Boccursin only 1–3 percent of the patients. Development of inhibitors appears equally likely in patients receiving plasma-derived replacement therapy and those receiving recombinant products.11 Among those patients with inhibitors, a fraction c an be desensitized and can again become responsive to factor replacement, although this process is time consuming and expensive.. In most cases, the approved population requires rFVIIa to bypass these inhibitors and promote clotting only during bleeding crises or for surgery and procedures. During the past decade, however, off-label use of rFVIIa has transitioned from infrequent use to more frequent applications for which evidence may be limited.

## Introduction to rFVIIa

### Procoagulant Products Preceding rFVIIa

The broad therapeutic territory occupied by rFVIIa involves situations where life-threatening bleeding is occurring or anticipated to occur in the absence of treatment alternatives. Its FDA-approved indication of use in hemophilia not amenable to standard factor concentrate therapy is a narrow niche within this broader spectrum of use. Prior to the advent of rFVIIa in 1998, therapeutic options included drugs that facilitate clotting and predecessor products derived from pooled human blood. Products derived from pooled blood samples carry the potential for the transmission of human viruses and increased allergic reactions.

For the FDA-approved indication in hemophilia, rFVIIa has virtually replaced procoagulant products that preceded it. Prior to the manufacture of rFVIIa, human-derived and purified FVII was occasionally used in hemophilia patients with inhibitors, but the mainstay of therapy were Factor Eight Inhibitor Bypassing Agent (FEIBA) followed historically by aPCC. These products also were used outside of hemophilia, but their range of indications has been far narrower than for rFVIIa.12 FEIBA is a heterogeneous and variable concentrate of vitamin -K-dependent human clotting factors derived from pooled human plasma. It is not clear which component or components are vital for its function. The function of FEIBA may depend on its concentration of rFVIIa.13 Activated Prothrombin Complex Concentrate (aPCC) is the successor to FEIBA. It is similar to FEIBA in that it is a human-derived concentrate of clotting factors, but it is processed to convert these into their active forms. This product is FDA-approved only for use in hemophilia patients with inhibitors.

There is also a range of other situation-specific procoagulant soften used with limited success in situations where rFVIIa is now used off-label. Protamine is used for heparin reversal and vitamin K is used for subacute reversal of warfarin anticoagulation. The lysine analogues epsilon-aminocaproic acid and tranexamic acid are fibrinolysis inhibitors and are used for bleeding in a wide range of medical conditions and surgical procedures, and are still often used in conjunction with rFVIIa. Aprotinin, a serine protease inhibitor, was used in patients in some surgical procedures with a risk of massive bleeding (e.g., coronary artery bypass grafting (CABG) and other cardiac surgeries) but was removed from the market in November 2007 because of evidence of increased morbidity and mortality.14–16 Since that time, there has been a shift toward use of tranexamic acid during cardiac surgery.

### rFVIIa Biology

rFVIIa is a form of activated human factor VII produced through recombinant technology. The molecule is 406 amino-acids in length and has a molecular weight of 50 kDaltons. As a protein-based therapy, it must begiven intravenously to facilitate coagulation at sites of bleeding and has a half-life of 2.5 hours. Currently, Novoseven^®^ is the only form of rFVIIa available commercially. rFVIIa is also known by its international nonproprietary name of activated eptacog alfa, although this term is infrequently used. rFVIIa promotes clotting in two ways:

1. At physiologic levels and in association with tissue factor (e.g., on damaged tissue), it activates factors IX and X to initiate the clotting cascade that ultimately leads to formation of a thrombin plug, which allows for clot stability. This normal physiological mechanism suggests that rFVIIa’s action is targeted to areas of tissue damage.
2. In pharmacological doses, it also binds to activated platelets and drives the process of thrombin clot formation forward via factor X activation, even in the absence of tissue factor. This mechanism is relatively specific to areas of tissue damage because clotting is fostered primarily where platelet aggregation occurs, the first step in the clotting process.17–19

These mechanisms effectively bypass portions of the clotting process that are normally required for clotting to occur. Thus, clotting can occur despite factor deficiencies (in factors VII, VIII, IX, and XI) or when the number or function of platelets is reduced.

### History of rFVIIa

The development of rFVIIa, under the brand name Novoseven,^®^ began in 1985 by Novo Industries of Bagsværd, Denmark (which became Novo Nordisk in a 1989 merger). rFVIIa was developed as an injectable procoagulant for use in hemophilia A or B with inhibitors (antibodies that inactivate exogenous factor VIII or factor IX, respectively). Use of human plasma derived factor VIIa was reported in 1983.^20^ The first published report of r FVIIa use was in 1989.^21^ Between 1989 and 1999, rFVIIa was provided on a compassionate basis by the manufacturer for use in Hemophilia A or B with inhibitors. The first non-hemophilia-related use was reported for the clinical indication of thrombocytopeniain 1996. 22 Since 1999, the FDA has approved four separate applications that have gradually expanded the scope of rFVIIa use for hemophilia:

1. Hemophilia A or B with inhibitors for bleeding episodes (March 25, 1999).
2. Bleeding and surgery in congenital factor VII deficiency (July 11, 2005).
3. Surgery and invasive procedures in Hemophilia A or B with inhibitors (August 12, 2005).
4. Bleeding and surgery in acquired hemophilia (October 13, 2006).

On November 25, 2005, the FDA required Novo Nordisk to make changes in drug labeling and issue a warning letter regarding the possibility of increased arterial thrombotic adverse events with rFVIIa use based on trial results for intracerebral hemorrhage (ICH), a subset of intracranial hemorrhage.23 Furthermore, in January 2010, the FDA required that a “black box” warning be added to the drug labeling that highlights a possible increase in venous and arterial thromboembolic events with use.24 On May 9, 2008, the FDA approved Novoseven RT, a reformulated form of rFVIIa capable of being stored at room temperature rather than requiring refrigeration. The U.S. patent for Novoseven expires in February 2011.

Similar regulatory histories exist in most developed nations. The European Medicines Agency (EMEA) approved rFVIIa on February 23, 1996 for use in Hemophilia A or B with inhibitors and subsequently added the indications of Glanzmann’s thrombasthenia and congenital FVII deficiency. Novo Nordisk applied to the EMEA for approval of rFVIIa use in ICH on October 5, 2005, but withdrew this application on April 6, 2006. In Australia and New Zealand, rFVIIa is approved for prophylactic use in hemophilia with inhibitors (2008). The Japanese patent for Novoseven expired in 2008, while the European Union patent will expire in November 2010.

### New Forms of rFVIIa and Other Development Trends

The goals of development of alternatives to the current formulation of rFVIIa are to increase the effective half-life of rFVIIa so that dosing can be less frequent, to increase the rapidity of onset so that hemostasis occurs more promptly, and to increase the localization of therapeutic effect so that remote thromboembolic events do not occur. Several products are under development:

1. Novo Nordisk, with Neose Technologies (formerly of Horsham, PA), developed NN7128, a product with greater glycosylation and other changes that create a longer acting rFVIIa. Phase I clinical trials were completed before Neose sold the drug rights to Novo Nordisk.
2. Novo Nordisk is developing NN1731, an analogue of rFVIIa designed to deliver faster but sustainable hemostasis with greater potency than Novoseven rFVIIa. This product is now in Phase II trials.
3. Novo Nordisk is also developing a subcutaneously absorbed form of rFVIIa. This product is in Phase I trials.
4. Maxygen (Redwood City, CA) developed Maxy-VII as a form of rFVIIa with increased platelet binding and more glycosylation to increase product half-life. Although approved for Phase I trials in 2008 by the FDA, these have not yet been conducted.
5. Factor VIIa-albumin fusion protein, with a reported 6–9 fold increase in half-life, is being developed by CLS Behring (King of Prussia, PA).
6. Bio Affinity Company (Naarden, Netherlands) is developing a version of rFVIIa to be produced by transgenic cows, a less expensive production strategy than cell culture.

Recombinant factor XIII is another Novo Nordisk product currently undergoing testing as a hemostatic agent in cardiac surgery patients. This glycoprotein facilitates clotting by cross -linking fibrin molecules, a process that stabilizes nascent, unstable clots. This mechanism may lead to less risk of inappropriate thrombosis because factor XIII acts only at the site of early clots, rather than participating in new clot formation.

### Off-Label Indications

The use of rFVIIa for off-label clinical indications originates in rFVIIa’s ability to “bypass” multiple defects in the coagulation pathway. These uses can be defined by their relative proximity to the FDA approved uses. The following categories suggest increasing extension of rFVIIa use into clinical areas with diminishing similarity to the FDA approved uses.

1. Chronic prophylactic use in Hemophilia A and B in the absence of bleeding episodes or procedures. While not approved by the FDA, this form of use has been approved in Australia.
2. Episodic use in other congenital and acquired clotting factor defects, including Hemophilia C, von Willebrand’s disease, and factor VII deficiency, as well as in other rare coagulopathies.
3. Episodic use for isolated congenital or acquired clotting defects that arise from deficiency or dysfunction of other components of the coagulation process. This includes platelet dysfunction, such as Glanzmann’s thrombasthenia, which has been approved by the EMEA but not the FDA.
4. Episodic use in disease states where impaired coagulation is but one manifestation. Liver disease is a prominent example, but other conditions include leukemia, lymphoma, and other cancers.
5. Episodic use where anticoagulant therapy contributes to bleeding problems beyond what would exist otherwise. This includes patients on warfarin and those undergoing cardiac surgery with cardiopulmonary bypass that requires heparin anticoagulation.
6. Clinical circumstances where a consumptive coagulopathy has developed as the result of substantial and rapid blood loss. In practice, this often includes trauma patients and those with massive gastrointestinal bleeding.
7. Situations where significant blood loss is anticipated in the absence of pre-existing coagulopathy, as with prophylactic use of rFVIIa in prostatectomy or vascular surgery.
8. Clinical situations where prompt cessation of traumatic, surgical or spontaneous bleeding in non-coagulopathic patients is needed because hemorrhage extension is associated with significant adverse outcomes, as occurs with intracranial hemorrhage, brain surgery, and pulmonary hemorrhage.

Among these categories, there is less rationale for an effectiveness review of the first three (#1–3). These uses are closely connected with the FDA approved uses, are relatively infrequent and difficult to study, and may have been scrutinized by other national drug review systems. For these reasons, we have not examined in detail the off-label uses that comprise these categories, but do present data evaluating trends related to these clinical indications. The other categories warrant considerable attention given their high prevalence and their biological remoteness from use in hemophilia. The purpose of this report is to evaluate the evidence of rFVIIa use for five specific off-label indications that cover at least some aspects of the remaining categories of rFVIIa application: intracranial hemorrhage, massive bleeding from trauma, liver transplantation, cardiac surgery, and prostate surgery.

## Past Systematic Reviews as Context for the Report

As we review in greater detail in the Discussion section, there have been a number of systematic reviews published on rFVIIa use for a variety of off-label indications, including some of those under consideration in this report. 25–63 The most recent systematic reviews have largely concluded that there is insufficient evidence to fully evaluate the benefits or harms of rFVIIa. As a generalization across off-label clinical indications, and in the aggregate, these past reviews suggest that for rFVIIa use compared to usual care:

1. There is limited evidence of clinical benefit for some indications when measured by indirect/surrogate end-points.
2. There is insufficient evidence available to evaluate the impact of rFVIIa use on direct clinical outcomes such mortality and functional status.
3. The evidence is inconclusive, but there are are non-significant trends that suggest an increase in thromboembolic harms for some indications.

These past systematic reviews varied in their quality of methodology and in the types and quality of the studies included. Given the ambiguity of past reviews, the rapid expansion of knowledge on off-label use, and practice trends that are outstripping the available evidence, reevaluation of the current literature on off-label rFVIIa use is warranted.

## Clinical Considerations of Heterogeneity

In contemplating this task, we noted that some prior systematic reviews pooled data from studies that assessed multiple disparate clinical indications. We felt that evaluation of rFVIIa globally required combining conditions that are so clinically heterogenous that the results were likely to be extremely difficult to interpret. So we agreed, in general, with the different approach encompassed in the original Key Questions of the report, which differentiate by clinical indication of use. We acknowledge, however, that selection of the appropriate degree of specificity is difficult and may be controversial. For instance, as discussed in detail below, we determined that certain subgroups within trauma and cardiac surgery warranted further division beyond what was originally encompassed in the Key Questions, and, therefore, we chose to evaluate these subgroups separately. We also included within each Key Question a section on qualitative considerations of heterogeneity to provide further context for our decisions to pool or not pool data from individual studies or particular patient populations.

## Areas of Anticipated Challenge

We identified a number of areas of anticipated challenges for our review.

Lack of comparison to predecessor products. No prior studies compare rFVIIa to predecessor products that might be considered alternative therapies in certain clinical scenarios (e.g., aPCC, aminocaproic acid, and tranexamic acid). This means that rFVIIa is compared to “usual care” for the evaluations of effectiveness.

Comparisons to usual care. Unlike a comparison to an alternative pharmaceutical agent, comparisons to usual care are particularly susceptible to bias. Site-to-site variations in usual care inevitably exist, and this lack of comparator uniformity may be substantial for trials conducted in multiple centers and multiple countries. In addition, advances in usual care may evolve over time, which creates additional heterogeneity, diminishes the relevance of past comparisons to current practice, and may diminish the marginal benefit of rFVIIa added to “usual care.”

Manufacturer with intensive involvement in research studies. Novo Nordisk’s sponsorship and involvement in rFVIIa clinical research is extensive, as might be expected of a manufacturer producing the only available product in a drug class. Its likely role in past decisions about research topics and design creates a potential conflict of interest. While these circumstances are not infrequent and do not equate with biased research findings, it does require special care in evaluating the possibility of bias in published studies examining rFVIIa’s use for off-label indications. At the same time, the manufacturer has funded studies on off-label uses of rFVIIa that would otherwise likely have not been undertaken.

Use of drug in emergency situations. In 1996, the FDA and Departments of Health and Human Services issued new guidelines on the study of drugs in emergency situations, allowing for a deferral of informed consent in a rule commonly referred to as Emergency Medicine Exception From Informed Consent.64,65 While policies and practices in Europe are in flux,66 similar allowances are made in some European countries.67 In the United States, the exception can be made only when the following criteria are met: the condition being studied is acute and life threatening, current therapies are inadequate, the window of opportunity for intervention is brief, it is not possible to obtain informed consent from the patient or legally authorized representative, there is the potential of direct benefit to the participant, and the risks of participation are reasonable in proportion to the potential benefits. These criteria might apply in a number of indications covered in this effectiveness review, namely intracranial hemorrhage, traumatic bleeding, and, in some cases, bleeding related to surgery. Patients may withdraw their “deferred consent” at such time as they are able to do so, which de facto occurs after randomization. The withdrawals can occur in a differential fashion based on the participant’s ability to survive long enough to object to enrollment. Thus, one can imagine a situation in which a group with more favorable survival actually has an increased rate of withdrawal solely on the basis of withdrawal of deferred consent by the patients who have lived long enough to object to being enrolled in a study. Note that this issue does not imply the lack of ethical trial conduct, but represents a potential difficulty in interpreting the results of these trials.

Variability in dose, repeat dosing, and prophylactic versus rescue use of rFVIIa. Studies vary widely in the doses of rFVIIa used. This issue is most challenging when rFVIIa is used in dose escalation studies. In the absence of demonstrable dose-effect relationships, inclusion of all doses may be reasonable. Studies also vary in their protocols regarding the acceptability of repeat dosing. Finally, within some clinical indications, separate studies evaluate use of rFVIIa as prophylaxis or treatment therapy, which increases the potential heterogeneity of clinical context and patient characteristics.

Special subgroups within trauma and cardiac surgery. Within the trauma indication for rFVIIa use, patients who have bleeding associated with traumatic brain injury (TBI) form a distinct subgroup of patients, which can present unique challenges that overlap with—and yet are distinct from—the challenges faced in managing other types of trauma-related hemorrhage. Similarly, cardiac surgeries for congenital abnormalities, generally performed in infancy, can differ greatly from cardiac surgeries performed in adults. For these reasons, we anticipated the need to distinguish between these subgroups of patients with hemorrhage: patients with brain trauma versus body trauma, and patients undergoing pediatric versus adult cardiac surgery.

## Key Questions that Guide the Current Report

This report has two primary objectives:

1. To document the complete range of clinical indications where rFVIIa is being used off-label, including information on real-world in-hospital practice patterns and the clinical studies available to evaluate these uses
2. To provide a comparative effectiveness review of rFVIIa versus usual care for selected off-label clinical indications: intracranial hemorrhage, massive bleeding secondary to trauma, and the surgical procedures of liver transplantation, cardiac surgery, and prostatectomy.

We were guided in our exploration of these issues by a set of Key Questions developed in preparation for the project by AHRQ. Construction of these questions included substantial input from key stakeholders, as well as refinement by the research team during the initiation of the project. These Key Questions helped define the scope and approach of this project. As below, Key Question 1 pertains to our first objective of documenting the range of rFVIIa off-label use. Note that this focus on “patterns of use” is directed solely at in-hospital populations (which is the population to whom off-label rFVIIa is applied, not outpatient populations). The other Key Questions reflect the emphasis of this report on the selected indications.

### Key Question 1

Recombinant factor VIIa is being administered and studied in an increasingly wide range of disease conditions and patient populations beyond the scope of its current labeled indications. With the intent of providing an overview of the range of off-label clinical conditions for which rFVIIa has been administered and/or studied:

1. What are the different indications and populations for which rFVIIa has been used and/or studied outside the currently labeled indications?
2. What is the clinical setting, dosage range, study design/size, comparator, and outcomes measured in past comparative studies investigating off-label rFVIIa?

### Key Question 2

Considering patients presenting with intracranial bleeding:

1. Does rFVIIa use reduce mortality and/or disability compared with currently accepted usual care?
2. Are there subpopulations of patients based on demographic or clinical factors who are more likely to benefit from rFVIIa use?
3. Does rFVIIa use increase thrombosis-related events compared with usual care?
4. Are there subpopulations of patients based on demographic or clinical factors who are more likely to experience harm from the use of rFVIIa compared with usual care?
5. In whom do the benefits of rFVIIa use outweigh the harms (evidence of net benefit), and does net benefit vary by issues such as timing and dosage used?

### Key Question 3

Considering patients with acquired, coagulopathic massive bleeding from trauma:

1. Does rFVIIa use reduce mortality and/or disability compared with currently accepted usual care?
2. Are there subpopulations of patients based on demographic or clinical factors who are more likely to benefit from rFVIIa use?
3. Does rFVIIa use increase thrombosis-related events compared with usual care?
4. Are there subpopulations of patients based on demographic or clinical factors who are more likely to experience harm from the use of rFVIIa compared with usual care?
5. In whom do the benefits of rFVIIa use outweigh the harms (evidence of net benefit), and does net benefit vary by issues such as timing and dosage used?

### Key Question 4

Considering patients undergoing liver transplantation, cardiac surgery, or prostatectomy:

1. Does salvage and/or prophylactic rFVIIa use reduce mortality and/or disability and treatment-related outcomes compared with currently accepted usual care?
2. Are there subpopulations of patients based on demographic or clinical factors who are more likely to benefit from rFVIIa use?
3. Does rFVIIa use increase thrombosis-related events compared with usual care?
4. Are there subpopulations of patients based on demographic or clinical factors who are more likely to experience harm from the use of rFVIIa compared with usual care?
5. In whom do the benefits of rFVIIa use outweigh the harms (evidence of net benefit), and does net benefit vary by issues such as timing and dosage used?