# Future Research

## Evidence Gaps

Our review can usefully comment on evidence gaps for applications of rFVIIa to clinical indications in two ways: areas in which published studies exist but may not yet have been synthesized (as in a systematic review or meta-analysis) and areas in which rFVIIa is being used (as in the Premier database) but where no or few studies have been published.

Our review of the literature identified five RCTs and comparative observational studies on the use of rFVIIa in patients with liver disease but for indications other than liver transplantation. These might be a useful target for future evidence synthesis. Other indications examined in multiple studies include bleeding in obstetrics and gynecology and in hematologic disease states, for which we identified three comparative studies apiece (Table 12).

Our review of the Premier database also identified notable areas of rFVIIa use in clinical practice. Similar to areas targeted in the published literature, applications to patients with liver disease, even outside of liver transplantation, are frequent, as are those to patients with obstetrical hemorrhage, hematologic malignancies and disorders, and non-congenital clotting disorders. However, areas not explored in depth in the published literature but for which real-world application of rFVIIa are not insignificant include bleeding from non-variceal gastrointestinal sources unrelated to liver disease, aortic aneurysm, pulmonary sources, neurosurgery, and neonatal disease states (Table 15). Finally, the high mortality rates among patients on the Premier database who received rFVIIa suggests that community application may be more heavily weighted toward end-stage use than is use in the context of studies. This suggestion, in no way definitive, emphasizes another potential disjunct between community use and the evidence base available for analysis. While end-stage use of rFVIIa is likely extremely difficult to study, this is another potential area for future inquiry.

Of the areas covered by the Key Questions for this project, further research recommendations are described below according to the specific concern or clinical indication.

### Need for Better Delineation of Withdrawal of Deferred Consent

Our comparative effectiveness review has implications for future research on the treatment of patients with life-threatening bleeding. For instance, a comment is in order on those RCTs performed in emergency situations. These potentially operate under the purview of the FDA rule on enrollment of patients in extremis (or similar guidelines in other countries, which allows for deferral of informed consent. 64,65 However, patients (or their legal representatives) may withdraw at a subsequent time, when made aware of the study. This has the potential to introduce bias, albeit for ethical reasons that are unavoidable, via differential withdrawal of consent. Therefore, in the future, such studies should explicitly report on the treatment arm of those patients who do decide to withdraw their (deferred) consent, so that the potential for introduction of bias on the basis of differential withdrawal can be better assessed.

### Future Research by Indication

Intracranial Hemorrhage. Despite the promise of earlier studies, there is a lack of evidence of benefit for intracranial hemorrhage patients, specifically those with ICH, on clinically important outcomes. Thus, if future studies are undertaken, they might best target subgroups of patients who can reasonably be expected to benefit more than those already studied. Because post-hoc analyses suggest that early infusion of rFVIIa may be the most beneficial, such administration may warrant further investigation. In addition, because there are no RCTs investigating the use of rFVIIa in patients on anticoagulation therapy or those with isolated subdural or subarachnoid bleeding, these populations may merit careful study.

Body trauma. Given that the balance of benefits versus harms in this area may favor rFVIIa use, future studies appear warranted. Studies thus far have highlighted possible complex associations between the degree of acidosis, thrombocytopenia, and other markers of baseline injury severity and the impact of rFVIIa. Future studies might attempt to better delineate these relationships and attempt to identify subgroups of patients who might most benefit from therapy.

Brain trauma. Given the lack of evidence of benefit for rFVIIa use on direct outcomes, if future studies are undertaken, they might best target patients felt to be at increased risk for poor outcomes with usual care, such as those who require rapid neurosurgical intervention but can not tolerate the usual care approach of large volume plasma infusions (e.g., patients with congestive heart failure) to correct for the coagulopathy of trauma. Similarly, future studies might avoid enrolling patients who might reasonably be felt to be at increased risk for harm from rFVIIa, such as those with blunt injuries to the cerebral vessels.

Liver transplantation. Because there is little evidence to suggest benefit on direct outcomes of prophylactic use of rFVIIa, future studies might best focus on its therapeutic use or its use in special populations. Jehovah’s Witnesses are one such population in which rFVIIa therapy is being regularly applied during liver transplantation without systematic evaluation of its impact.

Adult cardiac surgery. There is moderate evidence to suggest that rFVIIa may increase the rate of thromboembolic events without having an effect on mortality. Because these findings are in the context of increasing community use of rFVIIa for this indication, future studies may be considered, but carefully so. Existing studies have raised the possibility that patients experience greater benefit when rFVIIa is given earlier rather than later during treatment use for massive post-operative bleeding, such that if future studies are undertaken, exploration of the issue of timing of administration would be useful.

Pediatric cardiac surgery. What little evidence there is on rFVIIa use for congenital heart surgery, from one RCT, indicates no benefit and the potential for harm in terms of a longer time to chest closure. Because of this, future studies might be undertaken with great care. In particular, patients who might reasonably be expected to be at higher risk for thromboembolism, such as those on ECMO, might need special consideration in terms of weighing potential benefits and harms.

Prostatectomy. We see little reason for future studies of prophylactic use of rFVIIa on this indication, given that current surgical approaches have diminished bleeding rates to low or even negligible amounts.