# Strength of Evidence and Applicability Assessment Forms

Assessment Form