# Study Abstraction Forms

Level 1 (Screening Title and Abstract) Abstraction Form

Level 2 (Full Text Article Screening) Abstraction Form

Level 3 Full Text Data Abstraction Form (Study Information and Quality Assessment)

Level 4 Full Text Article Data Abstraction Form for Intracranial Hemorrhage Studies

Level 4 Full Text Article Data Abstraction Form for Traumatic Bleeding Studies

Level 4 Full Text Article Data Abstraction Form for Liver Transplantation Studies

Level 4 Full Text Article Data Abstraction Form for Cardiac Surgery Studies

Level 4 Full Text Article Data Abstraction Form for Prostatectomy Studies