# Peer Reviewers

Jay Lozier, M.D, Ph.D., National Institutes of Health Clinical Center, Bethesda, MD

Dr Simon Stanworth/Prof Chris Hyde, NHSBT, John Radcliffe Hospital, Headington, Oxford

Richard P. Dutton, M.D., M.B.A., University of Maryland, Department of Anesthesiology, Baltimore, MD

M. Margaret Knudson, Department of Surgery, Ward 3A, San Francisco General Hospital, San Francisco, CA

Rochelle Fu, Methodologist/statistician from SRC

Maureane Hoffman, M.D., Ph.D., Durham VA Medical Center, Durham, NC

Stefan Mayer

Bertil Glader, M.D., Ph.D., Lucile Packard Children’s Hospital, Stanford, CA.

Per Falk, MD, PhD, Associate Professor, Vice President, Clinical Development, Medical & Regulatory Affairs, Novo Nordisk, Inc.