# Additional Analyses, Tables, and Figures

Appendix Table 1 Diagnostic hiearchy and ICD-9-CM diagnosis and procedure codes

Rank in Hierarchy | Description | ICD-9-CM Codes (PR for procedure codes) Coding based on the presence of any eligible code within a hospitalization
1 | Hemophilia A and B | 286.0, 286.1
2 | Hemophilia-related off-label | 286.2, 286.3, 286.4, 286.5, 287.1, 287.3, 287.9
3 | Brain trauma | 852, 853
4 | Body trauma | All E-codes except E85, E87, E92, E93, E94; PR 81–90, 92–95, 98
5 | Intracranial hemorrhage | 430, 431, 432
6 | Brain surgery | PR 1
7 | Pediatric cardiac surgery | PR 35, 36, 37 (except 37.2) and age <18
8 | Adult cardiac surgery | PR 35, 36, 37 (except 37.2) and age ≥18
9 | Obstetrics | 72, 73, 74, 75; PR 63, 64, 65, 66, 67 (except 67.8)
10 | Neonatal conditions | V3, 76, 77 (except for 76.0, 76.1, 76.2, 76.3) and age < 1 year
11 | Aortic aneurysm | 441
12 | Prostatectomy | PR 60
13 | Other vascular surgery | PR 39 (except 39.94, 39.95, 39.96)
14 | Liver transplantation | PR 50.5
15 | Liver biopsy | PR 50.1, 50.2
16 | Esophageal varices | 456.0, 456.1, 456.2
17 | Other liver disease | 571, 572
18 | Other gastrointestinal bleed | 530.4, 531–535, 537, 557, 562, 569, 578
19 | Other secondary hematological conditions | 287 (except 287.1, 287.3, 287.9), 446.6, 283.1, 286.6, 286.7, 286.9, 964.2, V58.61, V58.63, E585.2, E934.2
20 | Pulmonary disease | 786.3, 770.3; PR 32, 33, 34
21 | Cancer | 140–230
22 | Other surgical procedures | PR ≤87 (except 39.8)
23 | Other, without procedures | All remaining codes

Appendix Table 2 Characteristics of included studies: Sample sizes, patient age, rFVIIa dose, and outcomes

Study Design | Number of Studies | Total Number of rFVIIa Patients | rFVIIa Sample Size Range | rFVIIa Mean Age Range | rFVIIa Mean Dose Range, ug/kg | Important Outcomes Evaluated
| | | | | | Direct | Indirect
KQ2-4 Indications
Intracranial hemorrhage
RCT | 4 | 944 | 36–573 | 51–72 | 5–160 | Mortality, TE events, Functional outcome | Change in hematoma volume
Comparative observational | 4 | 88 | 5–46 | 60–77 | 10–100 | Mortality, TE events, Functional outcome | Change in hematoma volume
Non-comparative | 3 | 53 | 15–20 | 8–68 | 60–100 | Mortality, TE events, Functional outcome | Change in hematoma volume
Body trauma
RCT (1 article reports on 2 RCTs) | 2 | 139 | 139 | 29–33 | 400 | Mortality, TE events, ARDS | Transfusion requirements, Hospital/ICU length of stay
Comparative observational | 5 | 264 | 29–81 | 28–41 | 50–120 | Mortality, TE events, ARDS | Transfusion requirements, Hospital/ICU length of stay
Non-comparative | 4 | 204 | 15–108 | 7–38 | 74–140 | Mortality, TE events | Transfusion requirements
Brain trauma
RCT | 1 | 61 | 61 | 52 | 40–200 | Mortality, TE events | Change in hematoma volume
Comparative observational | 2 | 60 | 29–31 | 40 | NR | Mortality, TE events | Time to neurosurgery, Hospital/ICU length of stay
Non-comparative | 1 | 15 | 15 | 61 | 59 | - | -
Liver transplantation
RCT | 4 | 209 | 10–121 | 49–53 | 20–360 | Mortality, TE events | Transfusion requirements, Blood loss, Hospital/ICU length of stay, Operating time
Comparative observational | 4 | 51 | 6–28 | 13–48 | 20–80 | Mortality, TE events | Transfusion requirements, Blood loss, Hospital/ICU length of stay, Operating time
Non-comparative | 0 | - | - | - | - | - | -
Adult cardiac surgery
RCT | 2 | 114 | 10–104 | 63–70 | 40–90 | Mortality, TE events | Transfusion requirements, Blood loss, Hospital/ICU length of stay
Comparative observational | 6 | 191 | 17–51 | 56–70 | 19–100 | Mortality, TE events | Transfusion requirements, Blood loss, Hospital/ICU length of stay, Need for surgical re-exploration
Non-comparative | 11 | 1125 | 16–503 | 51–68 | 10–103 | Mortality, TE events | Transfusion requirements, Blood loss, Need for surgical re-exploration
Pediatric cardiac surgery
RCT | 1 | 40 | 40 | 0.33 | 63 | TE events | Transfusion requirements, Blood loss, Time to chest closure
Comparative observational | 3 | 48 | 9–24 | 0.03–9 | 43–282 | TE events | Transfusion requirements, Blood loss, Need for surgical re-exploration
Non-comparative | 0 | - | - | - | - | - | -
Prostatectomy
RCT | 1 | 24 | 24 | 61–64 | 20–40 | Mortality, TE events | Transfusion requirements, Blood loss, Hospital/ICU length of stay, Operating time
Comparative observational | 0 | - | - | - | - | - | -
Non-comparative | 0 | - | - | - | - | - | -
KQ1 Indications:
Other liver disease
RCT | 4* | 517 | 71–170 | 46–55 | 5–800 | Mortality, TE events | Transfusion requirements, Blood loss, Efficacy of bleeding control
Comparative observational | 1 | 7 | 7 | 34 | 40–80 | Mortality | Transfusion requirements, Efficacy of bleeding control, Ability to place ICP transducer
Obstetrics/gynecology
RCT | 0 | - | - | - | - | - | -
Comparative observational | 3 | 50 | 6–26 | 29–34 | 70–100 | Mortality, TE events | Transfusion requirements, Blood loss
Hematology/oncology
RCT | 2 | 93 | 16–77 | 9–23 | 100–1120 | Mortality, TE events | Transfusion requirements, Efficacy of bleeding control
Comparative observational | 1 | 24 | 24 | NR | NR | Mortality, TE events | Requirement for positive pressure ventilation, Hospital/ICU length of stay
Other surgery
RCT | 4 | 191 | 9–122 | 44–56 | 20–360 | Mortality, TE events | Transfusion requirements, Blood loss, Operating time, Hospital/ICU length of stay
Comparative observational | 2 | 55 | 26–29 | 17–60 | 23 | Mortality, TE events, Functional outcome | Transfusion requirements, Blood loss
Total
RCT | 24 | 2310 | 9–573 | 0.33–72 | 5–1120
Comparative observational | 31 | 756 | 5–81 | 0.03–71 | 17–120

RCT=randomized controlled trial; TE=thromboembolic; ICU=intensive care unit

Appendix Table 3 Mortality and thromboembolic events in studies included in harms analyses

Article | Study Design | Sample Size | Mean Age (SD) [Range] | Mean Dose (ug/kg) (SD) [Range] | Mortality | TE Rate
Intracranial hemorrhage
Mayer 2005a23 (3 arms) | RCT | 108 | 67 (12) | 40 | 0.18 | 0.06
Mayer 2005a23 (3 arms) | RCT | 92 | 65 (12) | 80 | 0.18 | 0.04
Mayer 2005a23 (3 arms) | RCT | 103 | 64 (13) | 160 | 0.19 | 0.10
Mayer 2005b86 (6 arms) | RCT | 6 | 51 (9) | 10 | 0 | 0
Mayer 2005b86 (6 arms) | RCT | 6 | 68 (22) | 20 | 0 | 0.33
Mayer 2005b86 (6 arms) | RCT | 6 | 68 (16) | 40 | 0.17 | 0.33
Mayer 2005b86 (6 arms) | RCT | 6 | 58 (11) | 80 | 0 | 0
Mayer 2005b86 (6 arms) | RCT | 6 | 64 (14) | 120 | 0.17 | 0
Mayer 2005b86 (6 arms) | RCT | 6 | 53 (12) | 160 | 0.17 | 0
Mayer 2006^87^ (4 arms) | RCT | 8 | 72 (10) | 5 | 0.25 | 0
Mayer 2006^87^ (4 arms) | RCT | 8 | 60 (15) | 20 | 0.25 | 0.25
Mayer 2006^87^ (4 arms) | RCT | 8 | 64 (13) | 40 | 0.38 | 0.13
Mayer 2006^87^ (4 arms) | RCT | 8 | 62 (12) | 80 | 0 | 0
Mayer 2008^88^ (2 arms) | RCT | 276 | 65 (14) | 20 | 0.18 | 0.09
Mayer 2008^88^ (2 arms) | RCT | 297 | 65 (13) | 80 | 0.21 | 0.12
Pickard 2000^90^ | Comparative Observational | 5 | NR | 80 | NR | 0.20
Brody 2005^91^ | Comparative Observational | 12 | 71 (13.1) | NR | 0.42 | 0.17
Hallevi 2008^92^ | Comparative Observational | 46 | 59.6 [38–87] | 80^U^ [40;80] | 0.13 | 0.15
Ilyas 2008^89^ | Comparative Observational | 15 | 76.5 (11) | 24 [10–100] | 0.21 | 0.04
Sutherland 2008^93^ | Non-Comparative Observational | 15 | 68.0^U^ [25–81] | 60^U^ [40–92] | 0.13 | 0
Nussbaum 2009^95^ | Non-Comparative Observational | 18 | 56.8 | 100 | 0.22 | 0.44
Herbertson 2008^94^ | Non-Comparative Observational (Pediatric) | 20 | 7.7 | 100 | 0.15 | 0
Body trauma
Boffard 2005^96^ (blunt arm) | RCT | 69 | 33 (13) | 400 | 0.25 | 0.03
Boffard 2005^96^ (penetrating arm) | RCT | 70 | 29 (10) | 400 | 0.24 | 0.06
Rizoli 2006^97,a^ | Comparative Observational | 38 | 36.8 [30.6–43.1] | NR | 0.50 | NR
Nascimento 2008^181,a^ | Comparative Observational | 72 | NR | NR | NR | 0.10
Harrison 2005^101^ | Comparative Observational | 29 | 40.9 (20.8) | 60 [40–80] | 0.41 | 0.07
Fox 2009^99^ | Comparative Observational | 53 | 27.5 (9.5) | 100 [90–120] | 0.07 | 0.12
Dutton 2004^100,b^ | Comparative Observational | 81 | 40.8 (21) | 97.8 | 0.58 | NR
Cameron 2007^102^ | Non-Comparative Observational | 108 | 38.0^U^ [11–91] | 90^U^ [78–105]^I^ | 0.42 | 0.03
Felfernig 2007^103^ | Non-Comparative Observational | 45 | 30.5 [5–81] | 73.6 (27) | 0.24 | NR
Thomas 2007^228,b^ | Non-Comparative Observational | 242 | 44.0 (21) | 68& (45) | NR | 0.11
Martinowitz 2005^104^ | Non-Comparative Observational | 36 | 19.5 [14–65] | 140^U^ [70–540] | 0.39 | NR
Perkins 2007^182,c^ | Non-Comparative Observational | 53 | 23.1 | 109& | 0.34 | 0.02
Alten 2009^105^ | Non-Comparative Observational (Pediatric) | 15 | 7 | 88 | 0.13 | 0.07
Herbertson 2008^94^ | Non-Comparative Observational (Pediatric) | 37 | 7.7 | 100 | 0.22 | 0
Brain trauma
Narayan 2008^106^ (5 arms) | RCT | 12 | 51.5 (21.5)^ | 40 | 0 | 0.17
Narayan 2008^106^ (5 arms) | RCT | 11 | 29.9 (25.3) | 80 | 0 | 0.18
Narayan 2008^106^ (5 arms) | RCT | 14 | 29.9 (25.3) | 120 | 0.07 | 0.21
Narayan 2008^106^ (5 arms) | RCT | 12 | 29.9 (25.3) | 160 | 0.17 | 0
Narayan 2008^106^ (5 arms) | RCT | 12 | 29.9 (25.3) | 200 | 0.33 | 0.17
Stein 2008^107,b^ | Comparative Observational | 29 | 29.9 (25.3) | [8–140] | 0.35 | 0.21
Bartal 2007^109^ | Non-Comparative Observationl | 15 | 61.0 (11) | 59& [40–90] | 0.07 | 0
Liver Transplantation
Pugliese 2007^112^ | RCT | 10 | NR | 40 | NR | 0
Lodge 2005^110^ (2 arms) | RCT | 63 | 53.3 (11.2) | 180 | 0.02^#^ | 0.19
Lodge 2005^110^ (2 arms) | RCT | 58 | 52.6 (9.2) | 360 | 0.03^#^ | 0.12
Planinsic 2006^111^ (3 arms) | RCT | 18 | 49.4 (13.4) | 20 | 0.06^#^ | 0.11^*^
Planinsic 2006^111^ (3 arms) | RCT | 24 | 49.7 (10.1) | 40 | 0.08^#^ | 0.04^*^
Planinsic 2006^111^ (3 arms) | RCT | 22 | 51.9 (8.8) | 80 | 0.05^#^ | 0.09^*^
Liu 2009^113^ | RCT | 14 | 51.9 [36–54] | 47.5 {41–65] | NR | 0
Hendriks 2001^114^ | Comparative Observational | 6 | 43^U^ [37–61] | 80 | 0 | 0.17
Kalicinski 2005^116^ | Comparative Observational | 28 | 13.2 (4.2) | 51.5 [30–100] | 0.07 | 0
Niemann 2006^117^ | Comparative Observational | 11 | 48 (15) | 58 (18) | 0 | 0
De Gasperi 2005^115^ | Comparative Observational | 6 | 45 (4) | 30& [20–40] | 0 | NR
Adult Cardiac Surgery
Diprose 2005^118^ | RCT | 9 | 63^U^ [59–66]^I^ | 90 | 0 | 0.22
Gill 2009^119^ (2 arms) | RCT | 35 | 63.6^ | 40 | 0.11 | 0.09
Gill 2009^119^ (2 arms) | RCT | 68 | 63.6^ | 80 | 0.09 | 0.06
Gelsomino 2008^121^ | Comparative Observational | 40 | 70.1 (9.2) | 18^U^ [9–16]^I^ | 0.05 | 0.05
von Heymann 2005^123^ | Comparative Observational | 26 | 63.5 (12.87) | 89.3& | 0.38 | 0
Bowman 2008^124^ | Comparative Observational | 36 | 58 | 100& | 0.08 | 0.11
Trowbridge 2009^125^ | Comparative Observational | 17 | 70 (9) | NR | NR | NR
Tritapepe 2007^122^ | Non-Comparative Observational | 23 | 62.4 (9.4) | 82& | 0.13 | 0.09
Karkouti 2006^215,d^ | Non-Comparative Observational | 114 | 59.0 (17) | 56 (25) | 0.16 | 0.20
Dunkley 2008^133^ | Non-Comparative Observational | 293 | 63.0 (15) | 92.3^U^ [82–103]^I^ | 0.17 | 0.14
Filsoufi 2006^126^ | Non-Comparative Observational | 17 | 65.0 (18) | 103.1 (30.2) | 0.29 | NR
Gandhi 2007^127^ | Non-Comparative Observational | 17 | 53.0 [38–64] | 78.3 [24–189] | 0.29 | 0.24
Hyllner 2005^128^ | Non-Comparative Observational | 24 | 60.0 [34–82] | 72.2& [19.2–104] | 0.29 | NR
McCall 2006^129^ | Non-Comparative Observational | 53 | 68.0 [55–75]^I^ | 90 (15) | 0.19 | NR
Raivio 2005^130^ | Non-Comparative Observational | 16 | 60 (14.9) | 65 [24–192] | 0.25 | 0.25
Aggarwal 2004^131^ | Non-Comparative Observational | 24 | 65.0^U^ [26–85] | 90 | 0.75 | NR
Karkouti 2008^132^ | Non-Comparative Observational | 503 | 62.0 (15) | 62^U^ [40–89]^I^ | 0.32 | 0.24
Bruckner 2009^134^ (2 doses) | Non-Comparative Observational | 32 | 51 | 15 | 0 | 0.09
Bruckner 2009^134^ (2 doses) | Non-Comparative Observational | 30 | 51 | 20 | 0.87 | 0.37
Masud 2009^135^ | Non-Comparative Observational | 93 | 60.6 | 56.2 | 0.23 | 0
Hsia 2009^136^ | Non-Comparative Observational | 23 | NR | NR | NR | 0.39
Pediatric Cardiac Surgery
Ekert 2006^137^ | RCT | 40 | 0.33 | 63 [40–80] | NR | 0
Agarwal 2007^138^ | Comparative Observational | 24 | 0.0^U^ [0.01–6.53] | 59.8& | NR | 0.08
Tobias139 | Comparative Observational | 9 | 9 (4) | 90 | NR | 0
Niles 2008^140^ (2 groups) | Comparative Observational | 11 | 60 days (99) | 166 [76–282] | 0 | 0
Niles 2008^140^ (2 groups) | Comparative Observational | 4 | 14.5 | 286 [26–956] | 0 | 0
Prostatectomy
Friederich 2003^141^ (2 arms) | RCT | 8 | 61 (8.9) | 20 | 0 | 0.13
Friederich 2003^141^ (2 arms) | RCT | 16 | 64 (8.5) | 40 | 0 | 0

Fair+ Comparative Observational, fair or good quality comparative observational studies also included in the effectiveness review in Key Questions 2–4; Variance (e.g. standard deviation, range, or IQR) left blank if not reported.

U Median

I Interquartile Range

^ Mean age (and standard deviation) for all study arms combined.

# Mortality is underestimated because 2 deaths each in Lodge et al.110 and Planinsic et al.111 were not reported by treatment arm.

* Thromboembolic events are underestimated because only arterial thromboembolic events were counted in Planinsic et al.111

& Mean dose estimated from mean or median size of individual doses, or converted from mg to ug/kg by assuming an average patient weight.

a Nascimento et al.181 was used instead Rizoli et al.97 for the analysis of thromboembolic events. Nascimento et al. is a continuation of Rizoli et al. with more patients.

b Dutton et al.100 and Thomas et al.228 have overlapping patient populations. Dutton et al. was used for the mortality analysis and Thomas et al. was used in the analysis of thromboembolic events for body trauma. Thomas et al. included traumatic brain injury patients, some of which were included in Stein et al.107 Thus, some patients are double counted between the brain trauma and the body trauma analyses of thromboembolic events.

c Data on mortaility and thromboembolic events from Perkins et al.182 (an overlapping non-comparative study) are used instead of Spinella et al.98 (a comparative observational study analysed in the body trauma section above) because the former has a larger sample size.

d Data from the 2006 study by Karkouti et al.215 was used instead of the 2005 study by Karkouti et al.120 The 2006 study is an overlapping non-comparative study with more patients.

Appendix Table 4 Clinical trials on the off-label use of rFVIIa that are registered on an online database

Trial ID | Topic | Sponsor | End date | Primary associated publications
Key Question 2-4 Indications
Novo Nordisk trial # F7ICH-1389 | Intracranial hemorrhage | Novo Nordisk | Oct 2002 | Article: 2005^86^
Novo Nordisk trial # F7ICH-2073 | Intracranial hemorrhage | Novo Nordisk | Mar 2003 | Article: 2006^87^
NCT00426803 | Intracranial hemorrhage | Novo Nordisk | Jun 2004 | Article: 2005;^23^
NCT00222625 | Intracranial hemorrhage | University of Perugia | Sep 2006 | Article: 2008^238^
NCT00127283 | Intracranial hemorrhage | Novo Nordisk | Feb 2007 | Article: 2008^239^
NCT0026606 | Intracranial hemorrhage | Novo Nordisk | Apr 2007 | None^*^
NCT00128050 | Intracranial hemorrhage | IRCCS Policlinico S. Matteo | Dec 2008 | None
NCT00770718 | Intracranial hemorrhage | University of Utah | Apr 2010 | NA
NCT00810888 | Intracranial hemorrhage | University of Cincinnati | Apr 2013 | NA
Novo Nordisk trial # F7TRAUMA-2159 | Body trauma (2 RCTs merged)^ | Novo Nordisk | Sep 2003 | Article: 2005^96^
NCT00184548 merged with NCT00323570 | Body trauma (2 RCTs merged)^ | Novo Nordisk | Sep 2008 (terminated)^†^ | None^*^
NCT 00123591 | Brain trauma | Novo Nordisk | May 2006 | Article: 2008^106^
Novo Nordisk trial # F7LIVER-1256 | Liver transplantation | Novo Nordisk | Sep 2003 | Article: 2005^110^
NCT00154427 | Adult cardiac surgery | Novo Nordisk | Nov 2007 (terminated)^‡^ | Article: 2009^119^
NCT00214656 | Adult cardiac surgery | Austin Health | Jun 2008 | None
Novo Nordisk trial # F7CPB-3343 | Pediatric cardiac surgery | Novo Nordisk | NS | Article: 2006^137^
Other Indications
Novo Nordisk trial # F7- 3015 | Children with dengue hemorrhagic fever | Novo Nordisk | Dec 2002 | Article: 2005^150^
Novo Nordisk trial # F7LIVER-1313 | Partial hepatectomy in patients with cirrhosis | Novo Nordisk | Dec 2002 | Article: 2006^144^
Novo Nordisk trial # F7BMT-1360 | Allogenic stem cell transplantation | Novo Nordisk | Oct 2003 | Article: 2005^151^
Novo Nordisk trial # F7SCT-1485 | Allogenic stem cell transplantation | Novo Nordisk | Oct 2003 (terminated)^§^ | None^*^
Novo Nordisk trial # F7HAEM-2080 | Hemorrhagic cystitis | Novo Nordisk | Nov 2003 | Article: 2006^240^
NCT00104455 | Bleeding in healthy volunteers | Novo Nordisk | Nov 2004 | Abstracts 2005^241–243^
Novo Nordisk trial # F7ORTHO-1506 | Acetabular reconstruction surgery | Novo Nordisk | Mar 2005 | Article: 2005^154^
NCT0010237 | Spinal surgery | Novo Nordisk | Feb 2006 | Article: 2007^156^
NCT00154492 | Variceal bleeding | Novo Nordisk | Aug 2006 | Abstract 2007^244^
Novo Nordisk trial # F7HAEM-1825 | Bleeding in healthy volunteers treated with warfarin | Novo Nordisk | Jul 2008 | None^*^
NCT00370877 | Postpartum hemorrhage | Centre Hospital University of Nimes | Dec 2009 | NA
NCT00192933 | Hemorrhage^††^ | Rigshospitalet, Denmark | Dec 2010 | NA
NCT00243243 | Burns | United States Army Institute of Surgical Research | Dec 2010 | NA

NA=not applicable. NS=not stated (checked via applicable websites and subsequent publications)

* Synopsis of results available at Novo Nordisk website: www.novonordisk.com (last accessed 10/19/09)

^ According to manufacturer web site, each of these trials included 2 related RCTs: one directed at patients with blunt trauma and the other at patients with penetrating trauma.

† According to the manufacturer web site, “The decision to discontinue the F7TRAUMA-1711 trial is not due to any safety concerns. The result of the pre-planned futility analysis performed in June 2008 predicted a very low likelihood of reaching a successful outcome on the primary efficacy endpoint at the end of the trial and as a consequence, the company has decided to close the trial as this juncture.”

‡ According to manufacturer web site, “The trial was terminated after recruiting 172 patients but without proceeding to the highest dosing cohort as this no longer reflects common clinical practice.”

§ According to the manufacturer web site, “Trial enrollment of this study was prematurely terminated due to excessively slow patient recruitment.”

†† May be a prospective cohort study, rather than a clinical trial.

Appendix Table 5 Non-English language articles on key questions 2-4 indications excluded on the basis of language

Article citation | Language | Information available for review in English | Clinical indication | Patient information
RCT
Ma B, Wang ZN, Zhang BR. Effect of recombinant activated factor VII a on early recovery of patients undergoing cardiac valve replacement under cardiopulmonary bypass: a randomized double-blind placeb-controlled trial. Dier Junyi Daxue Xuebao. 2006;27(10):1110–3. | Chinese | Abstract and tables within full publication | Adult cardiac surgery | 11 rFVIIa, 11 placebo
Comparative observational study
Novak V, Mitov L, Rancić Z, Petrović B, Novak M. The use of recombinant activated factor VII in traumatic intracranial haemorrhage. Srpski Arhiv Za Celokupno Lekarstvo 2008;136 Suppl 3: 193–8. | Serbian | Abstract and tables within full publication | Brain trauma | 7 rFVIIa, number of controls unclear
Case report, case series, or registry
Grintescu I, Tulbure D, Mirea L. [Activated recombinant factor VII (Novoseven) in multiple trauma patients: an outcome analysis]. Chirurgia (Bucuresti). 2006;101(6):615–24. | Romanian | Abstract | Body trauma | 34 patients
Dementyeva II, Sandrikov VA, Charnaya MA, Morozov YA, Trekova NA, Eremenko AA. The “NovoSeven” (rFVIIa) hemostatic in massive hemorrhages in patients operated on the heart and aorta. Anesteziologiya i Reanimatologiya. 2004(5):11–13. | Russian | Abstract | Adult cardiac surgery | 25 patients
Dementyeva II, Gladysheva VG, Charnaya MA, Morozov YA. Influence of recombinant activated factor VIIa thrombocytic hemostasis. Gematologiya i Transfuziologiya. 2005;50(6):12–15. | Russian | Abstract | Adult cardiac surgery | 15 patients
Dement’eva I, Gladysheva VG, Charnaia MA, Morozov Iu A. [On the mechanism of action of recombinant activated factor VII in massive non- hemophylic bleeding in cardiosurgical patients]. Vestn Ross Akad Med Nauk. 2006(12):21–5. | Russian | Abstract | Adult cardiac surgery | 35 patients
Gong ZY, Gao CQ, Xiao CS, et al. [The use of recombinant activated factor VII for blood loss after cardiovascular surgery]. Chung-Hua Wai Ko Tsa Chih [Chinese Journal of Surgery]. 2008;46(19):1497–501. | Chinese | Abstract | Adult cardiac surgery | 16 patients
Lacheva A, Georgiev S, Pilossoff V, Lazarov S, Mitev P. Administration of recombinant factor VIIA for the management of massive postoperative blood loss in children with congenital heart defects. Anaesthesiology and Intensive Care. 2008;35(2):3–8. | Bulgarian | Abtract | Pediatric cardiac surgery | 30 patients

Appendix Figure 1 Mortality in ICH (low rFVIIa dose, arcsine)

This figure depicts mortality in ICH for low rFVIIa dose (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size -0.039 (95%CI: -0.108 to 0.03) P value for Q statistic:0.028; I-Squared=55.31

Appendix Figure 2 Mortality in ICH (medium rFVIIa dose, arcsine)

This figure depicts mortality in ICH for medium rFVIIa dose (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size -0.03 (95%CI: -0.1 to 0.04) P value for Q statistic: 0.028; I-Squared=55.31

Appendix Figure 3 Mortality in ICH (high rFVIIa dose, arcsine)

This figure depicts mortality in ICH for high rFVIIa dose (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size -0.037 (95%CI: -0.153 to 0.079) P value for Q statistic: 0.028; I-Squared=55.31

Appendix Figure 4 Poor modified Rankin score in ICH (low rFVIIa dose, arcsine)

This figure depicts poor modified Rankin score in ICH for low rFVIIa dose (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size -0.021 (95%CI: -0.091 to 0.05) P value for Q statistic: 0.086; I-Squared=43.9

Appendix Figure 5 Poor modified Rankin score in ICH patients (medium rFVIIa dose, arcsine)

This figure depicts poor modified Rankin score in ICH patients for medium rFVIIa dose (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size -0.026 (95%CI: -0.097 to 0.044) P value for Q statistic: 0.086; I-Squared=43.92

Appendix Figure 6 Poor modified Rankin score in ICH (high rFVIIa dose, arcsine)

This figure depicts poor modified Rankin score in ICH for high rFVIIa dose (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size -0.034 (95%CI: -0.151 to 0.082) P value for Q statistic: 0.086; I-Squared=43.92

Appendix Figure 7 Arterial thromboembolic events in ICH (low rFVIIa dose, arcsine)

This figure depicts arterial thromboembolic events in ICH for low rFVIIa dose (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size 0.086 (95%CI: 0.017 to 0.154) P value for Q statistic: 0.002; I-Squared=67.91

Appendix Figure 8 Arterial thromboembolic events in ICH (medium rFVIIa dose, arcsine)

This figure depicts arterial thromboembolic events in ICH for medium rFVIIa dose (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size 0.099 (95%CI: 0.029 to 0.169) P value for Q statistic: 0.002; I-Squared=67.91

Appendix Figure 9 Arterial thromboembolic events in ICH (high rFVIIa dose, arcsine)

This figure depicts arterial thromboembolic events in ICH for high rFVIIa dose (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size 0.169 (95%CI: 0.056 to 0.282) P value for Q statistic: 0.002; I-Squared=67.91

Appendix Figure 10 Mortality in adult cardiac patients (arcsine)

This figure depicts mortality in adult cardiac patients (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size 0.004 (95% CI: -0.099 to 0.108) P value for Q statistic: 0.38; I-Squared=2.1%

Appendix Figure 11 Sensitivity analysis for mortality in adult cardiac patients incorporating Chinese RCT (arcsine)

This figure depicts sensitivity for mortality in adult cardiac patients incorporating Chinese RCT (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size 0.005 (95% CI: -0.095 to 0.105) P value for Q statistic: 0.55; I-Squared=0%

Appendix Figure 12 All thromboembolic events in adult cardiac patients (arcsine)

This figure depicts all thromboembolic events in adult cardiac patients (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size 0.14 (95% CI: 0.038 to 0.242) P value for Q statistic: 0.78; I-Squared=0%

Appendix Figure 13 Sensitivity analysis for all thromboembolic events in adult cardiac patients incorporating Chinese RCT (arcsine)

This figure depicts sensitivity analysis for all thromboembolic events in adult cardiac patients incorporating Chinese RCT (using a random effects model with arcsine metrics). Summary statistics are as follows: Arcsine summary effect size 0.132 (95% CI: 0.033 to 0.232) P value for Q statistic: 0.83; I-Squared=0%