# Search Strategies

## OVID MEDLINE: 1948 to August 4, 2009

### Search 1: Factor VIIa Off-Label Use

Rather than trying to represent “off-label” use with MeSH terms or keywords, this search included any article on Factor VIIa except case reports, editorials, animal-only studies and non-systematic reviews. This search does include systematic reviews.

1. exp factor viia/OR(“factor viia” or “factor 7a” OR rfviia OR fviia) OR (novoseven or eptacog* OR Niastase OR proconvertin OR “novo-seven”) OR ec 3 4 21 21.rn. OR ((7a or viia) adj5 (factor OR rfactor)) OR ((“factor vii” OR “factor 7” OR fvii OR rfvii OR “factor seven”) adj5 (active OR activated))

2. case reports or editorial or “review”

3. animals/not humans/

1 NOT (2 OR 3 OR “ALL RESULTS FROM THE NEXT THREE SEARCHES”)

Number of citations: 1684

### Search 2: Intracranial Hemorrhages AND Factor VIIa

1. exp factor viia/OR (“factor viia” or “factor 7a” OR rfviia OR fviia) OR (novoseven or eptacog* OR Niastase OR proconvertin OR “novo-seven”) OR ec 3 4 21 21.rn. OR ((7a or viia) adj5 (factor OR rfactor)) OR ((“factor vii” OR “factor 7” OR fvii OR rfvii OR “factor seven”) adj5 (active OR activated))

2. exp Intracranial Hemorrhages/OR exp brain/OR exp skull/OR intracranial.mp. OR intracerebral.mp. OR “basal ganglia”.mp. OR brain*.mp. OR “posterior fossa”.mp. OR cerebral.mp. OR parenchymal.mp. OR subdural.mp. OR subarachnoid.mp. OR pituitary.mp. OR epidural.mp

3. animals/not humans/

(1 AND 2) NOT 3

Number of citations: 293

### Search 3: Trauma AND Factor VIIa

1. exp factor viia/OR (“factor viia” or “factor 7a” OR rfviia OR fviia) OR (novoseven or eptacog* OR Niastase OR proconvertin OR “novo-seven”) OR ec 3 4 21 21.rn. OR ((7a or viia) adj5 (factor OR rfactor)) OR ((“factor vii” OR “factor 7” OR fvii OR rfvii OR “factor seven”) adj5 (active OR activated))

2. exp “Wounds and Injuries”/OR (traum* or injur* or wound*).mp.

3. animals/not humans/

(1 AND 2) NOT 3

Number of citations: 459

Search 4: Liver Transplantation/Cardiac Surgery/Prostatectomy AND Factor VIIa

1. exp factor viia/OR (“factor viia” or “factor 7a” OR rfviia OR fviia) OR (novoseven or eptacog* OR Niastase OR proconvertin OR “novo-seven”) OR ec 3 4 21 21.rn. OR ((7a or viia) adj5 (factor OR rfactor)) OR ((“factor vii” OR “factor 7” OR fvii OR rfvii OR “factor seven”) adj5 (active OR activated))

2. exp liver transplantation/OR ((liver* or hepatic) adj3 (transplan* or graft*)).mp. OR exp Cardiovascular Diseases/su [Surgery] OR exp cardiovascular surgical procedures/OR ((heart* or cardi*) and surg*).mp.OR exp Prostatectomy/OR (Prostatectom* or (resect* and prostat*)).mp.

3. animals/not humans/

(1 AND 2) NOT 3

Number of citations: 294

Total number of citations from OVID/MEDLINE search: 3067

## EMBASE (DIALOG): 1974 to August 4, 2009

### Search 1: FACTOR VIIa NOT Letters, NOT Animal-only Studies

S1 | FACTOR VIIA! OR FACTOR()VIIA OR FACTOR()7A OR RFVIIA OR FVIIA OR NOVOSEVEN OR EPTACOG? OR NIASTASE OR PROCONVERTIN OR NOVO()SEVEN
S2 | (7A OR VIIA)(5N)(FACTOR OR RFACTOR)
S3 | (FACTOR()VII OR FACTOR()7 OR FVII OR RFVII OR FACTOR-()SEVEN)(5N)(ACTIVE OR ACTIVATED)
S4 | DT=LETTER
S5 | (ANIMALS/DE OR NONHUMANS/DE) NOT (HUMANS/DE OR HUMAN-/DE)
S6 | S1 OR S2 OR S3
S7 | S6 NOT (S4 OR S5)

### Search 2: FACTOR VIIa AND Intracranial Hemorrhage NOT Animal-only Studies

S9 | BRAIN! OR SKULL! OR INTRACRANIAL OR INTRACEREBRAL OR BASAL()GANGLIA OR BRAIN? OR POSTERIOR()FOSSA OR CEREBRAL OR PARENCHYMAL OR SUBDURAL OR SUBARACHNOID OR PITUITARY - OR EPIDURAL
S10 | BRAIN HEMORRHAGE! OR INTRACRANIAL HEMORRHAGES!
S11 | (STROKE! OR CVA OR STROKE OR APOPLEXY OR BRAIN()VASCULAR()ACCIDENT? OR CEREBROVASCULAR()ACCIDENT OR CEREBROVASCULAR ACCIDENT/DE) AND ( HEMORRHAGE! OR BLEEDING! OR HEMORRHAG? OR BLEED?)
S12 | S6 NOT S5
S13 | s12 AND (S24 OR S13 OR S18)

Search 3: FACTOR VIIa and Liver Transplantation/Heart Surgery/Prostatectomy NOT Animal-only Studies

S15 | LIVER TRANSPLANTATION!
S16 | (LIVER? OR HEPATIC)(5N)(TRANSPLANT? OR GRAFT?)
S17 | CARDIOVASCULAR SURGICAL PROCEDURES! OR CARDIOVASCULAR SURGERY!
S18 | CARDIOVASCULAR DISEASES!
S19 | S32(L)SU
S20 | CARDIOVASCULAR DISEASE!
S21 | S20(L)SU
S22 | (HEART? OR CARDI?) AND (SURG? OR PRESURG? OR POSTSURG? OR PERIOPERAT? OR OPERATION? OR OPERATIVE OR PERIOPERAT?OR PREOPERAT? OR POSTOPERAT? OR RESECT?)//TI,AB,DE
S23 | PROSTATECTOMY!
S24 | PROSTATECTOM? OR ((SURG? OR PRESURG? OR POSTSURG? OR PERIOPERAT? OR OPERATION? OR OPERATIVE OR PERIOPERAT? OR PREOPERAT? OR POSTOPERAT? OR RESECT?) AND PROSTAT?)
S25 | (S15–S24 combined with OR) AND S12

### Search 4: FACTOR VIIa and Trauma NOT Animal-only Studies

S27 | DC='C21.866.' (WOUNDS AND INJURIES)
S28 | TRAUM? OR INJUR? OR WOUND?
S29 | S12 AND (S27 OR S28)

Total number of citations from EMBASE search: 4424

## All OVID EBM Review Databases (Cochrane DSR, ACP Journal Club, DARE, CCTR, CMR, HTA, and NHSEED) No date restrictions. Searched up to August 4, 2009

### Factor VIIa Off-Label Use

“factor viia” or “factor 7a” OR rfviia OR fviia OR novoseven or eptacog* OR Niastase OR proconvertin OR “novo-seven” OR (7a or viia) adj5 (factor OR rfactor) OR (“factor vii” OR “factor 7” OR fvii OR rfvii OR “factor seven”) adj5 (active OR activated)

Number of citations: 161

## BIOSIS (ISI): 1926 to August 4, 2009

### Factor VIIa Off-Label Use

Broad search aimed at retrieving all articles on Factor VIIa, but excluding letters and animal-only studies.

“factor viia” or “factor 7a” OR rfviia OR fviia OR novoseven or eptacog* OR Niastase OR proconvertin OR “novo-seven” OR (7a or viia) adj5 (factor OR rfactor) OR (“factor vii” OR “factor 7” OR fvii OR rfvii OR “factor seven”) adj5 (active OR activated)

1 NOT Letters

2 NOT animals NOT humans

Number of citations: 3190

Total number of unique citations from all databases (after removing duplicate citations): 5668