# Appendixes

Appendix A Search Strategies

Appendix B List of Excluded Studies

Appendix C Additional Analyses, Tables, and Figures

Appendix D Peer Reviewers

Appendix E Study Abstraction Forms

Appendix F Strength of Evidence and Applicability Assessment Forms