# Acknowledgments

We are grateful to the following individuals for their hard work, assistance and contribution to this Comparative Effectiveness Review: Rose Campbell of the Oregon Health Sciences University, Michael Handrigan formerly of AHRQ, Robin Varghese of the University of Western Ontario, and Allison Gienger, Peter Richmond, Noelle Pineda, Rebecca Drieling, and Christine Wijman of Stanford University.

## Technical Expert Panel

- Richard P. Dutton, M.D., M.B.A., University of Maryland, Baltimore MD.
- Bertil Glader, M.D., Ph.D., Lucile Packard Children’s Hospital, Stanford CA.
- Lawrence T. Goodnough, M.D., Stanford Hospital and Clinics, Stanford CA.
- Maureane Hoffman, M.D., Ph.D., Duke University, Durham NC.
- John Holcomb, M.D., University of Texas Houston, Houston TX.
- M. Margaret Knudson, M.D., San Francisco General Hospital, San Francisco CA.
- Jay Lozier, M.D., Ph.D., National Institutes of Health Clinical Center, Bethesda MD.
- Kathryn O’Connell, M.D., M.P.H., Food and Drug Administration, Silver Spring MD.

## AHRQ Contacts

- Beth Collins Sharp, Ph.D., R.N.
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD