# Abbreviations

ACP Journal Club: American College of Physicians Journal Club
AHRQ: Agency for Healthcare Research and Quality
APACHE II: Acute Physiology And Chronic Health Evaluation
ARDS: Acute respiratory distress syndrome
BIOSIS: Bibliographic database covering worldwide research on all biological and biomedical topics. Records contain bibliographic data, indexing information, and abstracts for most references
BPH: Benign prostatic hypertrophy
CABG: Coronary artery bypass grafting
CCTR: Cochrane Central Register of Controlled Trials
CMR: Cochrane Methodology Register
CPB: Cardiopulmonary bypass
CT: Computed Tomography
DARE: Database of Abstracts of Reviews of Effectiveness
DRG: Diagnosis-related group
DVT: Deep vein thrombosis
ECMO: Extracorporeal membrane oxygenation
EMBASE: Biomedical database of bibliographic records produced by Elsevier
EMEA: European Medicines Agency
EPC: Evidence-based Practice Center
EU: European Union
FDA: Food and Drug Administration
FFP: Fresh frozen plasma
GCS: Glasgow Coma Scale
HTA: Health Technology Assessments
ICD-9: International Classification of Diseases, Ninth Revision
ICU: Intensive care unit
INR: International normalization ratio
ISS: Injury Severity Score
LOS: Length of stay
MeSH: Medical Subject Headings
MI: Myocardial infarction
MOF: Multiorgan failure
mRS: Modified Rankin Scale
NHSEED: NHS Economic Evaluation Database
NIHSS: NIH Stroke Scale
NNH: Number needed to harm
NNT: Number needed to treat
OLT: Orthotopic liver transplantation
OR: Operating room
PE: Pulmonary embolus
PubMed: Biomedical database of bibliographic records produced by the National Library of Medicine
RBCs: Red blood cells
RCT: Randomized controlled trial
rFVIIa: Recombinant Clotting Factor VIIa
SRC: Scientific Resource Center
TBI: Traumatic brain injury
TEP: Technical Expert Panel
UCSF: University of California, San Francisco
UK: United Kingdom
U.S.: United States