# References

1 Flegal KM, Kruszon-Moran D, Carroll MD, . Trends in Obesity Among Adults in the United States, 2005 to 2014. JAMA. 2016 Jun 07;315(21):2284–91. doi: 10.1001/jama.2016.6458. PMID: 27272580.27272580
2 Ogden CL, Carroll MD, Kit BK, . Prevalence of obesity and trends in body mass index among US children and adolescents, 1999–2010. JAMA. 2012 Feb 1;307(5):483–90. doi: 10.1001/jama.2012.40. PMID: 22253364.22253364
3 Ogden CL, Carroll MD, Curtin LR, . Prevalence of high body mass index in US children and adolescents, 2007–2008. JAMA. 2010 Jan 20;303(3):242–9. doi: 10.1001/jama.2009.2012. PMID: 20071470.20071470
4 Ogden CL, Carroll MD, Kit BK, . Prevalence of childhood and adult obesity in the United States, 2011–2012. JAMA. 2014 Feb 26;311(8):806–14. doi: 10.1001/jama.2014.732. PMID: 24570244.24570244
5 Global action plan for the prevention and control of noncommunicable diseases 2013–2020 World Health Organization. Geneva, Switzerland: Organization WH; 2013. http://apps.who.int/iris/bitstream/10665/94384/1/9789241506236_eng.pdf
6 Swinburn BA, Sacks G, Hall KD, . The global obesity pandemic: shaped by global drivers and local environments. Lancet. 2011 Aug 27;378(9793):804–14. doi: 10.1016/s0140-6736(11)60813-1. PMID: 21872749.21872749
7 Mokdad AH, Ford ES, Bowman BA, . Prevalence of obesity, diabetes, and obesity-related health risk factors, 2001. JAMA. 2003 Jan 01;289(1):76–9. PMID: 12503980.12503980
8 Peitz GW, Troyer J, Jones AE, . Association of body mass index with increased cost of care and length of stay for emergency department patients with chest pain and dyspnea. Circ Cardiovasc Qual Outcomes. 2014 Mar;7(2):292–8. doi: 10.1161/circoutcomes.113.000702. PMID: 24594550.24594550
9 Yusuf S, Hawken S, Ounpuu S, . Obesity and the risk of myocardial infarction in 27,000 participants from 52 countries: a case-control study. Lancet. 2005 Nov 05;366(9497):1640–9. doi: 10.1016/s0140-6736(05)67663-5. PMID: 16271645.16271645
10 Lu Y, Hajifathalian K, Ezzati M, . Metabolic mediators of the effects of body-mass index, overweight, and obesity on coronary heart disease and stroke: a pooled analysis of 97 prospective cohorts with 1.8 million participants. Lancet. 2014 Mar 15;383(9921):970–83. doi: 10.1016/s0140-6736(13)61836-x. PMID: 24269108.24269108
11 Arterburn DE, Maciejewski ML, Tsevat J. Impact of morbid obesity on medical expenditures in adults. Int J Obes (Lond). 2005 Mar;29(3):334–9. doi: 10.1038/sj.ijo.0802896. PMID: 15685247.15685247
12 Fitzgerald S, Kirby A, Murphy A, . Obesity, diet quality and absenteeism in a working population. Public Health Nutr. 2016 May 27:1–9. doi: 10.1017/s1368980016001269. PMID: 27230727.27230727
13 Gortmaker SL, Swinburn BA, Levy D, . Changing the future of obesity: science, policy, and action. Lancet. 2011 Aug 27;378(9793):838–47. doi: 10.1016/s0140-6736(11)60815-5. PMID: 21872752.21872752
14 Hammond RA. Complex systems modeling for obesity research. Prev Chronic Dis. 2009 Jul;6(3):A97. PMID: 19527598.19527598
15 Rossen LM, Schoendorf KC. Measuring health disparities: trends in racial-ethnic and socioeconomic disparities in obesity among 2- to 18-year old youth in the United States, 2001–2010. Ann Epidemiol. 2012 Oct;22(10):698–704. doi: 10.1016/j.annepidem.2012.07.005. PMID: 22884768.22884768
16 Committee on Evaluating Progress of Obesity Prevention Effort, Food and Nutrition Board, Institute of Medicine. Evaluating Obesity Prevention Efforts: A Plan for Measuring Progress. Washington DC: 2013 by the National Academy of Sciences; 2013.
17 Falbe J, Thompson HR, Becker CM, . Impact of the Berkeley Excise Tax on Sugar-Sweetened Beverage Consumption. Am J Public Health. 2016 Oct;106(10):1865–71. doi: 10.2105/ajph.2016.303362. PMID: 27552267.27552267
18 Elbel B, Kersh R, Brescoll VL, . Calorie labeling and food choices: a first look at the effects on low-income people in New York City. Health Aff (Millwood). 2009 Nov–Dec;28(6):w1110–21. doi: 10.1377/hlthaff.28.6.w1110. PMID: 19808705.19808705
19 Restrepo BJ. Calorie Labeling in Chain Restaurants and Body Weight: Evidence from New York. Health Econ. 2016 Jul 24doi: 10.1002/hec.3389. PMID: 27451966.27451966
20 Vadiveloo MK, Dixon LB, Elbel B. Consumer purchasing patterns in response to calorie labeling legislation in New York City. Int J Behav Nutr Phys Act. 2011 May 27;8:51. doi: 10.1186/1479-5868-8-51. PMID: 21619632.21619632
21 Dubowitz T, Ghosh-Dastidar M, Cohen DA, . Diet And Perceptions Change With Supermarket Introduction In A Food Desert, But Not Because Of Supermarket Use. Health Aff (Millwood). 2015 Nov;34(11):1858–68. doi: 10.1377/hlthaff.2015.0667. PMID: 26526243.26526243
22 Bere E, Veierod MB, Bjelland M, . Free school fruit--sustained effect 1 year later. Health Educ Res. 2006 Apr;21(2):268–75. doi: 10.1093/her/cyh063. PMID: 16219630.16219630
23 Bere E, Veierod MB, Klepp KI. The Norwegian School Fruit Programme: evaluating paid vs. no-cost subscriptions. Prev Med. 2005 Aug;41(2):463–70. doi: 10.1016/j.ypmed.2004.11.024. PMID: 15917042.15917042
24 Sisnowski J, Street JM, Merlin T. Improving food environments and tackling obesity: A realist systematic review of the policy success of regulatory interventions targeting population nutrition. PLoS One. 2017;12(8):e0182581. doi: 10.1371/journal.pone.0182581. PMID: 28783757.28783757
25 Executive summary: Guidelines (2013) for the management of overweight and obesity in adults: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the Obesity Society published by the Obesity Society and American College of Cardiology/American Heart Association Task Force on Practice Guidelines. Based on a systematic review from the The Obesity Expert Panel, 2013. Obesity (Silver Spring). 2014 Jul;22 Suppl 2:S5–39. doi: 10.1002/oby.20821. PMID: 24961825.24961825
26 Strategies to Prevent Obesity and Other Chronic Diseases: The CDC Guide to Strategies to Increase the Consumption of Fruits and Vegetables Centers for Disease Control and Prevention. Department of Health and Human Services; 2011. https://www.cdc.gov/obesity/downloads/strategies-fruits-and-vegetables.pdf
27 Strategies to Prevent Obesity and Other Chronic Diseases: The CDC Guide to Strategies to Increase Physical Activity in the Community Centers for Disease Control and Prevention. Atlanta, GA: U.S. Department of Health and Human Services; 2011. https://www.cdc.gov/obesity/downloads/PA_2011_WEB.pdf
28 Mastellos N, Gunn LH, Felix LM, . Transtheoretical model stages of change for dietary and physical exercise modification in weight loss management for overweight and obese adults. Cochrane Database Syst Rev. 2014 Feb 05(2):CD008066. doi: 10.1002/14651858.CD008066.pub3. PMID: 24500864.24500864
29 CHAMPS in the community. San Francisco, CA: University of California, San Francisco 2008. http://dne2.ucsf.edu/public/champs/community/action/index.html#sim. Accessed on August 14, 2017.
30 Orchard TJ, Temprosa M, Goldberg R, . The effect of metformin and intensive lifestyle intervention on the metabolic syndrome: the Diabetes Prevention Program randomized trial. Ann Intern Med. 2005 Apr 19;142(8):611–9. PMID: 15838067.15838067
31 National Diabetes Prevention Program. Atlanta, GA: Centers for Disease Control and Prevention; 2017. https://www.cdc.gov/diabetes/prevention/index.html. Accessed on August 14, 2017.
32 Obesity Treatment Options Setin Primary Care forUnderserved Populations: Pragmatic Clinical Trialsto Evaluate Real-World Comparative Effectiveness Patient-CenteredOutcomesResearchInstitute. Washington, D.C.: 2014. http://www.pcori.org/assets/2014/02/PCORI-PFA-2014-Spring-Obesity.pdf
33 About PCORnet. PCORnet. 2017. http://www.pcornet.org/about-pcornet/. Accessed on August 14, 2017.
34 Sonneville KR, Long MW, Ward ZJ, . BMI and Healthcare Cost Impact of Eliminating Tax Subsidy for Advertising Unhealthy Food to Youth. Am J Prev Med. 2015 Jul;49(1):124–34. doi: 10.1016/j.amepre.2015.02.026. PMID: 26094233.26094233
35 Economos CD, Hammond RA. Designing effective and sustainable multifaceted interventions for obesity prevention and healthy communities. Obesity (Silver Spring). 2017 Jul;25(7):1155–6. doi: 10.1002/oby.21893. PMID: 28653500.28653500
36 Mayne SL, Auchincloss AH, Michael YL. Impact of policy and built environment changes on obesity-related outcomes: a systematic review of naturally occurring experiments. Obes Rev. 2015 May;16(5):362–75. doi: 10.1111/obr.12269. PMID: 25753170.25753170
37 Wheeler BW, Gunnell D, Metcalfe C, . The population impact on incidence of suicide and non-fatal self harm of regulatory action against the use of selective serotonin reuptake inhibitors in under 18s in the United Kingdom: ecological study. BMJ. 2008 Mar 08;336(7643):542–5. doi: 10.1136/bmj.39462.375613.BE. PMID: 18276667.18276667
38 Mackay DF, Irfan MO, Haw S, . Republished paper: Meta-analysis of the effect of comprehensive smoke-free legislation on acute coronary events. Postgrad Med J. 2011 Apr;87(1026):311–6. doi: 10.1136/pgmj.2010.199026rep. PMID: 21459780.21459780
39 Pell JP, Haw S, Cobbe S, . Smoke-free legislation and hospitalizations for acute coronary syndrome. N Engl J Med. 2008 Jul 31;359(5):482–91. doi: 10.1056/NEJMsa0706740. PMID: 18669427.18669427
40 Sims M, Maxwell R, Bauld L, . Short term impact of smoke-free legislation in England: retrospective analysis of hospital admissions for myocardial infarction. BMJ. 2010 Jun 08;340:c2161. doi: 10.1136/bmj.c2161. PMID: 20530563.20530563
41 Medical Research Council. Using natural experiments to evaluate population health intervcentions. London, UK: Medical Research Council; 2010. https://www.mrc.ac.uk/documents/pdf/natural-experiments-to-evaluate-population-health-interventions/. Accessed on May 18, 2017.
42 Craig P, Cooper C, Gunnell D, . Using natural experiments to evaluate population health interventions: new Medical Research Council guidance. J Epidemiol Community Health. 2012 Dec;66(12):1182–6. doi: 10.1136/jech-2011-200375. PMID: 22577181.22577181
43 Ludwig J, Sanbonmatsu L, Gennetian L, . Neighborhoods, obesity, and diabetes--a randomized social experiment. N Engl J Med. 2011 Oct 20;365(16):1509–19. doi: 10.1056/NEJMsa1103216. PMID: 22010917.22010917
44 Stuart EA, Huskamp HA, Duckworth K, . Using propensity scores in difference-in-differences models to estimate the effects of a policy change. Health Serv Outcomes Res Methodol. 2014 Dec 01;14(4):166–82. doi: 10.1007/s10742-014-0123-z. PMID: 25530705.25530705
45 Whitlock EP, Lopez SA, Chang S, . AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol. 2010 May;63(5):491–501. doi: 10.1016/j.jclinepi.2009.03.008. PMID: 19540721.19540721
46 Mellor JM. Do cigarette taxes affect children’s body mass index? The effect of household environment on health. Health Econ. 2011 Apr;20(4):417–31. doi: 10.1002/hec.1598. PMID: 21394814.21394814
47 Department of Health and Human Services. The Surgeon General’s Call To Action To Prevent and Decrease Overweight and Obesity. Rockville MD; 2001.
48 The Human Development Index 2016. One World Nations Online; 2016. http://www.nationsonline.org/oneworld/human_development.htm. Accessed on August 14, 2017.
49 Woo Baidal JA, Nelson CC, Perkins M, . Childhood obesity prevention in the women, infants, and children program: Outcomes of the MA-CORD study. Obesity (Silver Spring). 2017 Jul;25(7):1167–74. doi: 10.1002/oby.21865. PMID: 28653498.28653498
50 Franckle RL, Falbe J, Gortmaker S, . Student obesity prevalence and behavioral outcomes for the massachusetts childhood obesity research demonstration project. Obesity (Silver Spring). 2017 Jul;25(7):1175–82. doi: 10.1002/oby.21867. PMID: 28653502.28653502
51 Taveras EM, Perkins M, Anand S, . Clinical effectiveness of the massachusetts childhood obesity research demonstration initiative among low-income children. Obesity (Silver Spring). 2017 Jul;25(7):1159–66. doi: 10.1002/oby.21866. PMID: 28653504.28653504
52 Helmerhorst HJ, Brage S, Warren J, . A systematic review of reliability and objective criterion-related validity of physical activity questionnaires. Int J Behav Nutr Phys Act. 2012 Aug 31;9:103. doi: 10.1186/1479-5868-9-103. PMID: 22938557.22938557
53 Measureas Registry Resources. National Collaboration on Childhood Obesity Research; 2014. http://nccor.org/nccor-tools/measures/other-resources. Accessed on September 1, 2016.
54 England CY, Andrews RC, Jago R, . A systematic review of brief dietary questionnaires suitable for clinical use in the prevention and management of obesity, cardiovascular disease and type 2 diabetes. Eur J Clin Nutr. 2015 Sep;69(9):977–1003. doi: 10.1038/ejcn.2015.6. PMID: 25711954.25711954
55 Cummins S, Flint E, Matthews SA. New neighborhood grocery store increased awareness of food access but did not alter dietary habits or obesity. Health Aff (Millwood). 2014 Feb;33(2):283–91. doi: 10.1377/hlthaff.2013.0512. PMID: 24493772.24493772
56 MacDonald JM, Stokes RJ, Cohen DA, . The effect of light rail transit on body mass index and physical activity. Am J Prev Med. 2010 Aug;39(2):105–12. doi: 10.1016/j.amepre.2010.03.016. PMID: 20621257.20621257
57 Kaushal N. Do food stamps cause obesity? Evidence from immigrant experience. J Health Econ. 2007 Sep 1;26(5):968–91. doi: 10.1016/j.jhealeco.2007.01.006. PMID: 17382418.17382418
58 Chen R, Smyser M, Chan N, . Changes in awareness and use of calorie information after mandatory menu labeling in restaurants in King County, Washington. Am J Public Health. 2015 Mar;105(3):546–53. doi: 10.2105/ajph.2014.302262. PMID: 25602868.25602868
59 Cheskin LJ, Frutchey R, McDermott AY, . Motivating systems-oriented research on environmental and policy changes for obesity prevention. Pediatr Obes. 2016 Apr 6doi: 10.1111/ijpo.12132. PMID: 27060703.27060703
60 Sturm R, Hattori A. Diet and obesity in Los Angeles County 2007–2012: Is there a measurable effect of the 2008 “Fast-Food Ban”? Soc Sci Med. 2015 May;133:205–11. doi: 10.1016/j.socscimed.2015.03.004. PMID: 25779774.25779774
61 Sekhobo JP, Edmunds LS, Dalenius K, . Neighborhood disparities in prevalence of childhood obesity among low-income children before and after implementation of New York City child care regulations. Prev Chronic Dis. 2014;11:E181. doi: 10.5888/pcd11.140152. PMID: 25321632.25321632
62 Schwartz AE, Leardo M, Aneja S, . Effect of a School-Based Water Intervention on Child Body Mass Index and Obesity. JAMA Pediatr. 2016 Mar;170(3):220–6. doi: 10.1001/jamapediatrics.2015.3778. PMID: 26784336.26784336
63 McKenzie TL, Cohen DA, Sehgal A, . System for Observing Play and Recreation in Communities (SOPARC): Reliability and Feasibility Measures. J Phys Act Health. 2006 Feb;3 Suppl 1:S208–S22. PMID: 20976027.20976027
64 Sugovic M, Turk P, Witt JK. Perceived distance and obesity: It’s what you weigh, not what you think. Acta Psychol (Amst). 2016 Mar;165:1–8. doi: 10.1016/j.actpsy.2016.01.012. PMID: 26854404.26854404
65 Brown BB, Smith KR, Tharp D, . A Complete Street Intervention for Walking to Transit, Nontransit Walking, and Bicycling: A Quasi-Experimental Demonstration of Increased Use. J Phys Act Health. 2016 Nov;13(11):1210–9. doi: 10.1123/jpah.2016-0066. PMID: 27334024.27334024
66 Brown BB, Werner CM, Tribby CP, . Transit Use, Physical Activity, and Body Mass Index Changes: Objective Measures Associated With Complete Street Light-Rail Construction. Am J Public Health. 2015 Jul;105(7):1468–74. doi: 10.2105/ajph.2015.302561. PMID: 25973829.25973829
67 Branas CC, Cheney RA, MacDonald JM, . A difference-in-differences analysis of health, safety, and greening vacant urban space. Am J Epidemiol. 2011 Dec 01;174(11):1296–306. doi: 10.1093/aje/kwr273. PMID: 22079788.22079788
68 Cohen DA, Marsh T, Williamson S, . Impact and cost-effectiveness of family Fitness Zones: a natural experiment in urban public parks. Health Place. 2012 Jan;18(1):39–45. doi: 10.1016/j.healthplace.2011.09.008. PMID: 22243905.22243905
69 Fitzhugh EC, Bassett DR, Jr., Evans MF. Urban trails and physical activity: a natural experiment. Am J Prev Med. 2010 Sep;39(3):259–62. doi: 10.1016/j.amepre.2010.05.010. PMID: 20709258.20709258
70 Merom D, Bauman A, Vita P, . An environmental intervention to promote walking and cycling--the impact of a newly constructed Rail Trail in Western Sydney. Prev Med. 2003 Feb;36(2):235–42. PMID: 12590999.12590999
71 Parker KM, Rice J, Gustat J, . Effect of bike lane infrastructure improvements on ridership in one New Orleans neighborhood. Ann Behav Med. 2013 Feb;45 Suppl 1:S101–7. doi: 10.1007/s12160-012-9440-z. PMID: 23334767.23334767
72 Human Development Reports. United Nations Development Programme. http://hdr.undp.org/en Accessed on August 14, 2017.
73 Taber DR, Chriqui JF, Powell LM, . Banning all sugar-sweetened beverages in middle schools: reduction of in-school access and purchasing but not overall consumption. Arch Pediatr Adolesc Med. 2012 Mar;166(3):256–62. doi: 10.1001/archpediatrics.2011.200. PMID: 22064875.22064875
74 Wright K, Norris K, Newman Giger J, . Improving healthy dietary behaviors, nutrition knowledge, and self-efficacy among underserved school children with parent and community involvement. Child Obes. 2012 Aug;8(4):347–56. doi: 10.1089/chi.2012.0045. PMID: 22867074.22867074
75 Liu J, Kuo T, Jiang L, . Food and drink consumption among 1–5-year-old Los Angeles County children from households receiving dual SNAP and WIC v. only WIC benefits. Public Health Nutr. 2016 Sep 9:1–8. doi: 10.1017/s1368980016002329. PMID: 27609603.27609603
76 Tester JM, Leung CW, Crawford PB. Revised WIC Food Package and Children’s Diet Quality. Pediatrics. 2016 May;137(5)doi: 10.1542/peds.2015-3557. PMID: 27244804.27244804
77 Slater S, Chriqui J, Chaloupka FJ, . Joint use policies: are they related to adolescent behavior? Prev Med. 2014 Dec;69 Suppl 1:S37–43. doi: 10.1016/j.ypmed.2014.08.032. PMID: 25199731.25199731
78 Kim J. Are physical education-related state policies and schools’ physical education requirement related to children’s physical activity and obesity? J Sch Health. 2012 Jun;82(6):268–76. doi: 10.1111/j.1746-1561.2012.00697.x. PMID: 22568462.22568462
79 Sabia JJ, Nguyen TT, Rosenberg O. High School Physical Education Requirements and Youth Body Weight: New Evidence from the YRBS. Health Econ. 2016 Aug 30doi: 10.1002/hec.3399. PMID: 27576770.27576770
80 Stephens RL, Xu Y, Lesesne CA, . Relationship between child care centers’ compliance with physical activity regulations and children’s physical activity, New York City, 2010. Prev Chronic Dis. 2014 Oct 16;11:E179. doi: 10.5888/pcd11.130432. PMID: 25321630.25321630
81 Webb E, Laverty A, Mindell J, . Free Bus Travel and Physical Activity, Gait Speed, and Adiposity in the English Longitudinal Study of Ageing. Am J Public Health. 2016 Jan;106(1):136–42. doi: 10.2105/ajph.2015.302907. PMID: 2656211826562118
82 Elbel B, Mijanovich T, Kiszko K, . The Introduction of a Supermarket via Tax-Credits in a Low-Income Area. Am J Health Promot. 2017 Jan;31(1):59–66. doi: 10.4278/ajhp.150217-QUAN-733. PMID: 26389982.26389982
83 Panter J, Heinen E, Mackett R, . Impact of New Transport Infrastructure on Walking, Cycling, and Physical Activity. Am J Prev Med. 2016 Feb;50(2):e45–53. doi: 10.1016/j.amepre.2015.09.021. PMID: 26585051.26585051
84 Burke RM, Meyer A, Kay C, . A holistic school-based intervention for improving health-related knowledge, body composition, and fitness in elementary school students: an evaluation of the HealthMPowers program. Int J Behav Nutr Phys Act. 2014 Jun 26;11:78. doi: 10.1186/1479-5868-11-78. PMID: 24969618.24969618
85 Flego A, Herbert J, Waters E, . Jamie’s Ministry of Food: quasi-experimental evaluation of immediate and sustained impacts of a cooking skills program in Australia. PLoS One. 2014;9(12):e114673. doi: 10.1371/journal.pone.0114673. PMID: 25514531.25514531
86 Wilcox HC, Kharrazi H, Wilson RF, . Data Linkage Strategies to Advance Youth Suicide Prevention: A Systematic Review for a National Institutes of Health Pathways to Prevention Workshop. Ann Intern Med. 2016 Oct 4doi: 10.7326/m16-1281. PMID: 27699389.27699389
87 Kharrazi H, Weiner JP. IT-enabled Community Health Interventions: Challenges, Opportunities, and Future Directions. EGEMS (Wash DC). 2014;2(3):1117. doi: 10.13063/2327-9214.1117. PMID: 25848627.25848627
88 Roalfe AK, Holder RL, Wilson S. Standardisation of rates using logistic regression: a comparison with the direct method. BMC Health Serv Res. 2008 Dec 29;8:275. doi: 10.1186/1472-6963-8-275. PMID: 19113996.19113996
89 Gorely T, Morris JG, Musson H, . Physical activity and body composition outcomes of the GreatFun2Run intervention at 20 month follow-up. Int J Behav Nutr Phys Act. 2011 Jul 18;8:74. doi: 10.1186/1479-5868-8-74. PMID: 21767356.21767356
90 Sigmund E, El Ansari W, Sigmundova D. Does school-based physical activity decrease overweight and obesity in children aged 6–9 years? A two-year non-randomized longitudinal intervention study in the Czech Republic. BMC Public Health. 2012 Jul 29;12:570. doi: 10.1186/1471-2458-12-570. PMID: 22892226.22892226
91 EPHPP: Quality Assessment Tool for Quantitative Studies. http://www.ephpp.ca/PDF/Quality%20Assessment%20Tool_2010_2.pdf. Accessed on August 14, 2017.
92 Eagle TF, Gurm R, Smith CA, . A middle school intervention to improve health behaviors and reduce cardiac risk factors. Am J Med. 2013 Oct;126(10):903–8. doi: 10.1016/j.amjmed.2013.04.019. PMID: 23932159.23932159
93 Taber DR, Chriqui JF, Chaloupka FJ. Differences in nutrient intake associated with state laws regarding fat, sugar, and caloric content of competitive foods. Arch Pediatr Adolesc Med. 2012 May;166(5):452–8. doi: 10.1001/archpediatrics.2011.1839. PMID: 22566546.22566546
94 Folta SC, Kuder JF, Goldberg JP, . Changes in diet and physical activity resulting from the Shape Up Somerville community intervention. BMC Pediatr. 2013 Oct 04;13:157. doi: 10.1186/1471-2431-13-157. PMID: 24093936.24093936
95 Sterne JA, Hernan MA, Reeves BC, . ROBINS-I: a tool for assessing risk of bias in non-randomised studies of interventions. BMJ. 2016 Oct 12;355:i4919. doi: 10.1136/bmj.i4919. PMID: 27733354.27733354
96 EPHPP: Quality Assessment Tool for Quantitative Studies. Effective Public Health Practice Project; 2009. http://www.ephpp.ca/tools.html. Accessed on November 17, 2016.
97 Armijo-Olivo S, Stiles CR, Hagen NA, . Assessment of study quality for systematic reviews: a comparison of the Cochrane Collaboration Risk of Bias Tool and the Effective Public Health Practice Project Quality Assessment Tool: methodological research. J Eval Clin Pract. 2012 Feb;18(1):12–8. doi: 10.1111/j.1365-2753.2010.01516.x. PMID: 20698919.20698919
98 Wells G. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Ottawa, Canada: Ottawa Hospital Research Institute; 2014. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed on May 18, 2017.
99 Basu S, Meghani A, Siddiqi A. Evaluating the Health Impact of Large-Scale Public Policy Changes: Classical and Novel Approaches. Annu Rev Public Health. 2017 Mar 20;38:351–70. doi: 10.1146/annurev-publhealth-031816-044208. PMID: 28384086.28384086
100 Population Health Methods: Difference-in-Difference Estimation. Columbia University. https://www.mailman.columbia.edu/research/population-health-methods/difference-difference-estimation. Accessed on November 2, 2017.
101 Greenland S. An introduction to instrumental variables for epidemiologists. Int J Epidemiol. 2000 Aug;29(4):722–9. PMID: 10922351.10922351
102 Baiocchi M, Cheng J, Small DS. Instrumental variable methods for causal inference. Stat Med. 2014 Jun 15;33(13):2297–340. doi: 10.1002/sim.6128. PMID: 24599889.24599889
103 Biglan A, Ary D, Wagenaar AC. The value of interrupted time-series experiments for community intervention research. Prev Sci. 2000 Mar;1(1):31–49. PMID: 11507793.11507793
104 Interrupted time series (ITS) analyses. EPOC Resources for review authors. The Cochrane Collaboration; 2017. http://epoc.cochrane.org/resources/epoc-resources-review-authors. Accessed on November 2, 2017.
105 Linden A, Adams JL, Roberts N. Evaluating disease management programme effectiveness: an introduction to the regression discontinuity design. J Eval Clin Pract. 2006 Apr;12(2):124–31. doi: 10.1111/j.1365-2753.2005.00573.x. PMID: 16579820.16579820
106 Imbens GW, Lemieux T. Regression discontinuity designs: A guide to practice. J Econom. 2008;142:615–35.
107 What Works Clearinghouse: Preview of Regression Discontinuity Design Standards. Institute of Education Sciences; 2015. https://ies.ed.gov/ncee/wwc/Document/258. Accessed on November 2, 2017.
108 Bauhoff S. The effect of school district nutrition policies on dietary intake and overweight: a synthetic control approach. Econ Hum Biol. 2014 Jan;12:45–55. doi: 10.1016/j.ehb.2013.06.001. PMID: 23891422.23891422
109 Ferdinand AO, Sen B, Rahurkar S, . The relationship between built environments and physical activity: a systematic review. Am J Public Health. 2012 Oct;102(10):e7–e13. doi: 10.2105/ajph.2012.300740. PMID: 22897546.22897546
110 Sarink D, Peeters A, Freak-Poli R, . The impact of menu energy labelling across socioeconomic groups: A systematic review. Appetite. 2016 Apr 1;99:59–75. doi: 10.1016/j.appet.2015.12.022. PMID: 26723238.26723238
111 Sacco J, Lillico HG, Chen E, . The influence of menu labelling on food choices among children and adolescents: a systematic review of the literature. Perspect Public Health. 2016 Jul 19doi: 10.1177/1757913916658498. PMID: 27436235.27436235
112 Sobol-Goldberg S, Rabinowitz J, Gross R. School-based obesity prevention programs: a meta-analysis of randomized controlled trials. Obesity (Silver Spring). 2013 Dec;21(12):2422–8. doi: 10.1002/oby.20515. PMID: 23794226.23794226
113 Wang Y, Wu Y, Wilson RF, . Childhood Obesity Prevention Programs: Comparative Effectiveness Review and Meta-Analysis. Rockville MD; 2013.
114 Gudzune K, Hutfless S, Maruthur N, . Strategies to prevent weight gain in workplace and college settings: a systematic review. Prev Med. 2013 Oct;57(4):268–77. doi: 10.1016/j.ypmed.2013.03.004. PMID: 23523689.23523689
115 Gee KA. School-Based Body Mass Index Screening and Parental Notification in Late Adolescence: Evidence From Arkansas’s Act 1220. J Adolesc Health. 2015 Sep;57(3):270–6. doi: 10.1016/j.jadohealth.2015.05.007. PMID: 26115907.26115907
116 Nguyen BT, Powell LM. Supplemental nutrition assistance program participation and sugar-sweetened beverage consumption, overall and by source. Prev Med. 2015 Dec;81:82–6. doi: 10.1016/j.ypmed.2015.08.003. PMID: 26303370.26303370
117 Gibson D. Long-term Food Stamp Program participation is positively related to simultaneous overweight in young daughters and obesity in mothers. J Nutr. 2006 Apr;136(4):1081–5. PMID: 16549483.16549483
118 Molitor F, Sugerman S, Yu H, . Reach of Supplemental Nutrition Assistance Program-Education (SNAP-Ed) interventions and nutrition and physical activity-related outcomes, California, 2011–2012. Prev Chronic Dis. 2015 Mar 12;12:E33. doi: 10.5888/pcd12.140449. PMID: 25764139.25764139
119 Leung CW, Blumenthal SJ, Hoffnagle EE, . Associations of food stamp participation with dietary quality and obesity in children. Pediatrics. 2013 Mar;131(3):463–72. doi: 10.1542/peds.2012-0889. PMID: 23439902.23439902
120 Hilmers A, Chen TA, Dave JM, . Supplemental Nutrition Assistance Program participation did not help low income Hispanic women in Texas meet the dietary guidelines. Prev Med. 2014 May;62:44–8. doi: 10.1016/j.ypmed.2014.01.016. PMID: 24530319.24530319
121 Wong SH, Huang WY, Cerin E, . Home and neighbourhood environment: association with children’s physical activity and obesity-related dietary behaviour. Hong Kong Med J. 2016 Dec;22 Suppl 6(6):43–7. PMID: 27807318.27807318
122 Thom G, Lean M. Is There an Optimal Diet for Weight Management and Metabolic Health? Gastroenterology. 2017 May;152(7):1739–51. doi: 10.1053/j.gastro.2017.01.056. PMID: 28214525.28214525
123 Maddock J, Takeuchi L, Nett B, . Evaluation of a statewide program to reduce chronic disease: The Healthy Hawaii Initiative, 2000–2004. Eval Program Plann. 2006;29(3):293–300. doi: 10.1016/j.evalprogplan.2005.12.007. PMID: 2006-11996-009.
124 National Health and Nutrition Examination Survey. Atlanta, GA: Centers for Disease Control and Prevention; 2017. https://www.cdc.gov/nchs/nhanes/.
125 Behavioral Risk Factor Surveillance System. Atlanta, GA: Centers for Disease Prevention; 2017. https://www.cdc.gov/brfss/. Accessed on May 18, 2017.
126 Fleurence RL, Curtis LH, Califf RM, . Launching PCORnet, a national patient-centered clinical research network. J Am Med Inform Assoc. 2014 Jul–Aug;21(4):578–82. doi: 10.1136/amiajnl-2014-002747. PMID: 24821743.24821743
127 Ackermann RT, Kenrik Duru O, Albu JB, . Evaluating diabetes health policies using natural experiments: the natural experiments for translation in diabetes study. Am J Prev Med. 2015 Jun;48(6):747–54. doi: 10.1016/j.amepre.2014.12.010. PMID: 25998925.25998925
128 Porta M. A Dictionary of Epidemiology. New York, NY: Oxford University Press; 2014. http://irea.ir/files/site1/pages/dictionary.pdf. Accessed on December 11, 2017.
129 Corriveau N, Eagle T, Jiang Q, . Sustained Benefit Over Four-Year Follow-Up of Michigan’s Project Healthy Schools. Am J Public Health. 2015 Dec;105(12):e19–25. doi: 10.2105/ajph.2015.302835. PMID: 26469650.26469650
130 Rosenbaum P, Rubin D. The central role of the propensity score in observational studies for causal effects. Biometrika. 1983;70(1):41–55.
131 Lee BY, Bartsch SM, Mui Y, . A systems approach to obesity. Nutr Rev. 2017 Jan;75(suppl 1):94–106. doi: 10.1093/nutrit/nuw049. PMID: 28049754.28049754
132 Johnston LM, Matteson CL, Finegood DT. Systems science and obesity policy: a novel framework for analyzing and rethinking population-level planning. Am J Public Health. 2014 Jul;104(7):1270–8. doi: 10.2105/ajph.2014.301884. PMID: 24832406.24832406
133 Methodology Committee of the Patient-Centered Outcomes Research Institute (PCORI). Methodological standards and patient-centeredness in comparative effectiveness research: the PCORI perspective. JAMA. 2012 Apr 18;307(15):1636–40. doi: 10.1001/jama.2012.466. PMID: 22511692.22511692