# Key Question 6 Methodological Advances

## Key Question (KQ) 6 What methodological/analytic advances (e.g., data system features, approaches to linking data sources, or analytic methods) would help to strengthen efforts to estimate the effect of programs, policies, or built environment changes on obesity prevention and control?

### Overview

KQ6 provided an opportunity to get feedback from experts in the field of obesity research about suggestions for methodological/analytic advances (e.g., data system features, approaches to linking data sources, or analytic methods) to strengthen efforts to estimate the effect of programs, policies or built environment changes on obesity prevention and control.

### Key Finding

- The internal advisors agreed about the importance of 24 methodological/analytic advances that the core research team suggested for strengthening efforts to estimate the effect of programs, policies, or built environment changes on obesity prevention and control.

### Methods

#### Data Abstraction

To address KQ 6 about the needs for methodological/analytic advances, we followed the following steps to engage our research team, internal advisors, and external experts:

1. We asked each investigator on the research team to suggest answers to KQ, 6 taking into consideration the results for KQ 1–5, and the following specific questions:
  a. What features or types of data sources could help researchers advance methods for conducting studies, especially natural experiments, of how programs, policies or built environment changes affect obesity prevention and control?
  b. What methodological advances would help to facilitate better or more frequent linkage of population-based data sources for studies, especially natural experiments, in obesity prevention and control?
  c. What methodological advances (e.g., measures and data collection procedures) would help to strengthen the assessment of obesity-related outcomes, including dietary and physical activity behaviors in studies, especially natural experiments, of how programs, policies or built environment changes affect obesity prevention and control?
  d. What study design and analytic approaches would help to strengthen methods and reduce the risk of bias encountered in studies, especially natural experiments, of how programs, policies or built environment changes affect obesity prevention and control?
2. We discussed the suggestions as a team and created a master list of unique items based on the consensus of the team.
3. We developed a form to elicit feedback about the list of methodological/analytic advances that could improve obesity prevention and control natural experiments (See Appendix F for the form).
4. We asked our internal advisors to review the form and provide input on the list. We chose the experts based on their expertise. All of the internal advisors have training and practice in health policy. Two experts have clinical expertise in obesity prevention and control (adults and children). Additionally, the internal advisors provide expertise in: economic decision making; cost-effectiveness; and housing, community planning, and urban development.
5. We obtained additional input from external technical experts about the suggested methodological/analytic advances that are needed by asking them to complete the form as part of their review of the draft of the evidence report.

#### Data Synthesis

For this report, we prepared a master list of methodological/analytic advances that would help strengthen efforts to estimate the effect of programs, policies, or built environment changes on obesity prevention and control, as developed the study team. At the request of the Pathways to Prevention Workshop planners, we did not prioritize the items on the list.

### Results

Our research team developed questions to elicit feedback from internal advisors and external experts about what methodological/analytic advances (e.g., data system features, approaches to linking data sources, or analytic methods) would help to strengthen efforts to estimate the effect of programs, policies or built environment changes on obesity prevention and control. We then developed several recommendations within each of these questions aligned with our KQs: KQs 1 and 2 were fcoused on identifying methodologic or analytic advances that may impact the frequency and better use of data sources in public health studies; KQ 3 was focused on identifying methodologic and analytic advances that would lead to more consistent reporting of obesity-realted outcomes and measures; KQs 4 and 5 were focused on identifying methodologic and analytic advances that would lead to more consistent use of terms in reporting study designs, as well as lead to more time series designs, natural experiment studies, and development and use of validated tools.

Table 14 summarizes these questions and the corresponding recommendations from our research team regarding methodological/analytic advances that could help to strengthen efforts to estimate the effect of programs, policies, or built environment changes on obesity prevention and control. These recommendations were then independently reviewed by our internal advisors and external experts having varied areas of relevant expertise (see Methods for details on area of expertise). The advisors agreed that 24 of the 26 items were important. The only items that were not endorsed by all advisors were the call for consistent use of a standard format for describing how data were collected and validated (including data quality control processes), and the call for requiring an explanation of how each data source was intended to be used, both addressing KQ1.

Table 14 Analytic and methodologic advances identified by internal and external experts

Key Question(s) | Form Question | Answers
1 | What features or types of data sources could help researchers advance methods for conducting studies, especially natural experiments, of how programs, policies or built environment changes affect obesity prevention and control? | A process that encourages and facilitates dissemination of publicly available information about the existence and location of data sources that include information about obesity-related outcomes.
1 | | A process that encourages and facilitates dissemination of publicly available information about the existence and location of data sources that include information about programs, policies, or built environment changes that could affect obesity prevention and control
1 | | Consistent use of standard terminology in data sources that include obesity-related information, including such concepts as: classification of interventions intended to contribute to obesity prevention and control (e.g., governmental program or policy, non-governmental program or policy, or built environment change); and units of measurement of obesity-related outcomes
1 | | Consistent use of data dictionaries and codebooks that define all elements, and that are readily accessible and searchable
1 | | Consistent use of a standard format for describing how data were collected and validated (including data quality control processes)
1 | | Explanation of how each data source was intended to be used
1 | | Description of the timing of interventions in data sources containing information about programs, policies, or built environment changes that could affect obesity prevention and control
1 | | Inclusion of BMI and other health behavior data in data sources covering small geographic areas
2 | What methodological advances would help to facilitate better or more frequent linkage of population-based data sources for studies, especially natural experiments, in obesity prevention and control? | Consistent use of standard procedures for linking health care data from different sources
2 | What methodological advances would help to facilitate better or more frequent linkage of population-based data sources for studies, especially natural experiments, in obesity prevention and control? | Development and use of new methods for linking data on social determinants of health with health care data
2 | What methodological advances would help to facilitate better or more frequent linkage of population-based data sources for studies, especially natural experiments, in obesity prevention and control? | Development of reporting standards by publishers for the description of how data sources are linked when studies report more than one data source in manuscripts
2 | What methodological advances would help to facilitate better or more frequent linkage of population-based data sources for studies, especially natural experiments, in obesity prevention and control? | Adoption of standard policies and procedures for exchanging/sharing data
3 | What methodological advances (e.g., measures and data collection procedures) would help to strengthen the assessment of obesity-related outcomes, including dietary and physical activity behaviors in studies, especially natural experiments, of how programs, policies or built environment changes affect obesity prevention and control? | Standardized measures and methods for obesity-related outcomes across populations and studies to better facilitate comparisons
3 | | Improving data collection measures for park-based and transportation-based studies to assess changes in individual and population physical activity beyond observing park or transportation use
3 | | Assessment of the validity of intermediate outcomes such as studies of food purchasing behavior correlated to behavioral and health outcomes
3 | | Longer term surveillance of measures to measure the impact of an intervention on changes in obesity measures over time
3 | | Inclusion of BMI and other health behavior data in data sources covering small geographic areas
3 | | Establishing standards for the collection of obesity-related outcomes in adults and children
3 | | Consistent use of validated measures of obesity-related outcomes across studies.
3 | | Consistent use of terminology in describing measures of obesity-related outcomes used in surveys or observational studies
4 and 5 | What study design and analytic approaches would help to strengthen methods and reduce the risk of bias encountered in studies, especially natural experiments, of how programs, policies or built environment changes affect obesity prevention and control? | Consistent use of standards for terms and reporting in studies of obesity prevention and control using natural experiment designs, including: study design, testing assumptions, sensitivity analyses, observed (and adjusted for) confounders, and unobserved confounders
4 and 5 | | Design-specific reporting standards for observational study methods used in natural experiments related to obesity prevention and control
4 and 5 | | Greater use of time-series designs instead of simple pre-post comparisons in studies of obesity prevention and control
4 and 5 | | Greater use of stronger natural experiment designs such as instrumental variables and regression discontinuity
4 and 5 | | Development and use of validated instruments for measuring the “exposures” in studies of how programs, policies, or built environment changes affect obesity prevention and control
4 and 5 | | Development and use of a specific practical and validated tool for assessing the risk of bias in observational studies of how programs, policies, or built environment changes affect obesity prevention and control

BMI=body mass index