# Key Question 5 Risk of Bias

## Key Question (KQ) 5 What are the risks of bias in studies of how programs, policies, or built environment changes affect or are associated with obesity prevention and control outcomes?

### Overview

This question aims to evaluate the risks of bias using a standard tool as well as supplemental study design-specific items to identify methodological/analytic advances that would help strengthen efforts to evaluate the effect of future programs, policies, and built environment changes related to obesity prevention and control

### Key Findings

- Most natural experiment studies were rated as having a “weak” global rating (i.e., high overall risk of bias), with 63 percent having a weak rating for handling of withdrawals and dropouts, 42 percent having a weak rating for study design, 40 percent having a weak rating for confounding, 26 percent having a weak rating for data collection.
- Among natural experiment studies, regression adjustment was the most common method to control for confounding (73%), followed by direct covariate matching or stratification (12%).

### Methods

#### Data Abstraction

To address KQ 5, we used three complementary approaches recognizing that no risk of bias tool has been specifically designed to assess natural experiment studies, and that all tools have their strengths and limitations. First, to enable comparisons across all study designs (both natural experiment studies and experimental studies), we chose to apply a single risk of bias assessment tool to be used across all studies. Second, we developed additional study design-specific risk of bias questions for the non-experimental designs commonly used in natural experiment studies, such as interrupted time series. Table 11 shows the most commonly encountered types of non-experimental study designs and specific bias concerns we considered relevant to assess. Third, we used an alternative risk of bias assessment tool for a randomly selected sample of the natural experiment studies. The overall intention was to focus on assessing the risk of bias, or internal validity of studies, rather than on applicability or external validity of studies.

Table 11 Analytic methods that can be used in non-experimental studies and specific bias concerns

Analytic Method | Definition | Key Assumptions | Specific Bias Concerns
Cross-sectional comparison of exposed and unexposed groups ^42^ | Compares exposed and unexposed groups at a single point in time Propensity score methods or regression adjustment can be used to adjust for observed confounders within this design. | Adjustment for observed confounders No unmeasured confounding | Confounding
Difference in differences ^99, 100^ | Compares exposed and unexposed groups before and after the exposure Takes advantage of variation across time and across groups | Unobserved differences between the two groups do not change over time; i.e., in the absence of the exposure, the trend in outcome in the two groups would be identical. | Changes over time (independent of exposure) that differentially affect exposed or unexposed group
Instrumental variable ^101, 102^ | Involves identifying an “instrument” that influences receipt of the program or policy of actual interest but does not directly influence the outcome; the instrument also needs to be, at least hypothetically, randomized. | Instrument is associated with receipt of the program or policy of interest (testable). Exclusion restriction: no direct effect of the instrument on the outcome; i.e., Instrument associated with outcome only through exposure Instrument randomized (no common cause with outcome), or at least conditionally randomized (conditional on observed factors) | Violation of exclusion restriction Non-randomization of instrument Weak instrument (not strongly predictive of exposure itself)
Interrupted time series^103, 104^ | Assesses change over time before and after a policy intervention Design stronger if also includes data on an untreated comparison group (in which case it is an extension of a difference-in-differences design to multiple time points). | Unobserved differences between groups are fixed No other “interruption” at the time of the policy change Groups would have identical changes in trends in absence of intervention. | Group composition changing over time Comparison group not providing accurate estimate of what would have happened in absence of intervention (e.g., if trends over time differ in unobserved ways between comparison and intervention sites) Change in measurement over time
Pre/Post ^42^ | Compares one group before and after an intervention, with the pre-intervention period serving as the control group for the post-intervention period. | No secular trend in the outcome | Changes over time unrelated to the exposure
Regression discontinuity ^105–107^ | Uses a cutoff/rule to assign intervention status; analysis compares those just above the cutoff to those just below the cutoff to estimate effect of the intervention | Smooth model relating the cutoff variable to the outcome in the absence of the intervention Intervention must have been assigned using the cutoff/rule | Unclear demarcation at cutoff Manipulation of cutoff variable near the cutoff Incorrect model specification above or below the cutoff

To assess risk of bias, our goal was to select a tool that could address many of the risk of bias concerns of natural experiment studies in a single scale. We chose the Effective Public Health Practice Project (EPHPP) tool because it was simple to apply, was interpretable across multiple study designs, and had been developed specifically for population-based programs and policies similar to studies in our systematic review. We considered a number of tools and compared The Risk Of Bias In Non-randomized Studies – of Interventions (ROBINS-I)^95^ against the tool from the EPHPP.^96^ The EPHPP tool was compared with an earlier version of the ROBINS tool and was shown to have fair inter-rater agreement, a notable challenge for the highly subjective process of risk of bias assessment.^97^ In its guidance about using natural experiments, the UK’s Medical Research Council ^41, 42^ suggested using the Newcastle-Ottawa Scale,^98^ a tool developed for observational studies. However, our review included both experimental and observational studies (see Scope of the Review in Methods) and therefore we could not apply the Newcastle-Ottawa Scale across all studies. The EPHPP tool yields individual scores of the domains and an overall classification of risk of bias, and addresses the risk of bias domains common to other tools like ROBINS and the Newcastle-Ottawa Scale.

We trained our risk of bias reviewers in applying the EPHPP tool. Two reviewers independently assessed each study’s risk of bias using six domains from the EPHPP tool for all studies:^96^ Table 12 displays the domains from the EPHPP, summarizes the included items, and describes the criteria for receiving a “weak rating.” Appendix D lists all the items for the EPHPP tool.

Table 12 Summary of Effective Public Health Practice Project quality assessment tool

Domain | Summary of Items | Criteria for Weak Rating
Selection bias | Representativeness of sample Participation rate | Sample not likely to be representative of target population; or participation rate less than 60%
Study design | Type of study design Randomization | Not reported or not RCT, CCT, cohort study, case control, or interrupted time series
Confounders | Baseline differences between groups Control for confounding | Less than 60% of identified confounders accounted for in analysis; or confounding not assessed/reported
Blinding | Blinding of outcome assessor Blinding of study participants | Both outcome assessor and study participants are not blinded
Data Collection Methods | Validity of data collection tools Reliability of data collection tools | Data collection tools not shown to be valid; or validity and reliability not described
Withdrawals and dropouts | Count and reasons for dropouts Percent completing study | Follow-up rate of less than 60%; or no report of attrition
Global Bias Rating | Summary of all six domains | Two or more weak ratings

CCT=controlled clinical trial; RCT=randomized controlled trial

Studies received domain-specific ratings as “strong”, “moderate” or “weak” according to the EPHPP algorithm ^96^. Each study also received a global risk of bias rating: “strong” if none of the domains were rated as weak, “moderate” if only one of the domains was rated as weak, or “weak” if two or more of the domains were rated as weak. For example, to assess selection bias the EPHPP has questions on whether the selected individuals were likely to be representative of the target population, and what percentage of selected individuals agreed to participate. The study would be rated as “weak” on the selection bias domain if: “the selected individuals are not likely to be representative of the target population and there is less than 60 percent participation, or the selected individuals are not described/can’t tell and the level of participation is not described/can’t tell.” Any study, including one with a non-experimental study design, could receive a “strong” global rating if it was not rated as “weak” in any of the domains.

While we found the EPHPP’s domains applicable to assessing the risk of bias in natural experiment studies, it was not specifically designed for these types of studies, as no tool exists specific to natural experiment studies. To supplement the EPHPP in addressing bias specific to natural experiment study designs, we additionally assessed the methods to address confounding and types of adjustment in all studies, and developed the design-specific risk of bias questions to assess specific threats to bias for each of the non-experimental designs listed in Table 10. In addition, in a subset (n=20) of randomly selected natural experiment studies, we used the Newcastle-Ottawa Scale for Cohort Studies to assess the risk of bias and compared results to those from the EPHPP tool (Appendix L).^98^

#### Data Synthesis

We described the risk of bias assessments across all studies and by type of study design. As described in the KQ 5 Methods, we used the EPHPP tool for all 294 studies to rate the risk of bias in the 6 domains of selection bias, study design, confounding, blinding, data collection, and withdrawals and dropouts (Appendix C). The EPHPP also provided a global bias rating based on the results across these 6 domains (Appendix C). We summarize the risk of bias ratings across studies by study design type: natural experiment studies, experimental studies, and other studies.

### Results

#### Risk of Bias in Natural Experiment Studies

Figure 8 shows EPHPP risk of bias ratings for the 156 natural experiment studies. The domains most likely to be rated as strong (i.e., low risk of bias) were data collection methods and confounding, but still only a minority of natural experiment studies were rated as strong in those domains: 74 (47%) for data collection, and 69 (44%) for confounding. EPHPP rates studies as “strong” in the domain of confounding if the researchers control for at least 80 percent of identified confounders, or if there were no important differences between exposed and unexposed groups at baseline. For example, one evaluation of the Los Angeles Fast Food Ban used the California Health Interview Survey to compare changes in diet and obesity outcomes among residents of areas affected by the ban compared to residents of areas not affected by the ban.^60^ In addition to selecting comparison neighborhoods, researchers controlled for both individual level and neighborhood level confounders: individual gender, age, race, household size and income, marital status and income; as well as neighborhood population density, median income, and racial composition. Studies received a “strong” rating in data collection methods if the data collection tools employed were shown to be both valid and reliable; for example, the use of the Recent Physical Activity Questionnaire to evaluate the impact of a new transit system on physical activity.^83^ See Appendix K for individual risk of bias ratings.

Figure 8 Risk of bias for natural experiment studies (N=156)

* Studies are given a “strong” global rating if there are no domains given a “weak” rating, a “moderate” global rating if there is a single domain with a “weak” rating, and a “weak” global rating if there are two or more domains with a “weak” rating.

Figure 8 illustrates the risk of bias assessment natural experiment studies. These studies rated strongly in the domains of selection bias, confounding, and data collection methods, meaning that risk of bias in these domains is low. They were rated as moderate or weak in the areas of study design, blinding, withdrawals and dropouts. Most natural experiment studies received a weak rating overall.

EPHPP’s selection bias domain covers the likelihood that the study participants are representative of the target population as well as the percentage of individuals who agree to participate. Forty-three natural experiment studies were rated “strong” on selection bias (28%); 98 studies (63%) were rated as “very likely” that the study sample was representative of the target population, but only 40 studies (25%) reported that 80 to 100 percent of selected individuals agreed to participate. Ninety-nine natural experiment studies were rated as “weak” (i.e., high risk of bias) in the domain of withdrawals and dropouts (64%). In 30 percent of natural experiment studies, withdrawals and dropouts were either not reported or not enough information was given for a reviewer to determine how attrition was handled. For example, one evaluation of a new bus line and pedestrian thoroughfare collected data from 1143 commuters at baseline, but was only able to collect limited follow-up data as many participants were lost from each group and for unclear reasons^83^.

The EPHPP risk of bias assessment tool rates only randomized controlled trials (RCTs) and controlled clinical trials as “strong” in the study design domain, therefore none of the natural experiments were rated as having “strong” study designs. EPHPP rates studies on blinding of both participants and outcome assessors to intervention status. Although blinding of outcome assessors may be possible in some natural experiment studies, blinding of participants often is not feasible. Thus, it is not surprising that few studies were rated strong in the domain of blinding.

Since confounding is a common source of bias in natural experiment studies, we examined the most commonly adjusted for control variables in natural experiment studies (see Table 13). This does not include the criteria on which comparison groups were matched among the studies that used, for example, a matched comparison community. Of the 156 studies, 24 percent controlled for community-level confounders, and 17 percent controlled for school or worksite level confounders. Controlling for individual-level variables such as age, race, gender, and household socioeconomic status, was more common. Four studies included a sensitivity analysis to explore robustness of the results to unobserved confounders.

Table 13 Common categories of control variables accounted for in natural experiment studies (N=156)

Category | Examples | n (%)
Age | Age, age categories, grade | 82 (52)
Race/ethnicity | Race, Hispanic ethnicity | 63 (40)
Sex or gender | | 94 (69)
Baseline measure of outcome | BMI or BMI category at baseline, physical activity at baseline | 32 (20)
Household socioeconomic status | Income, parental education, food security, eligibility for free lunch, welfare or SNAP recipient | 68 (43)
School characteristics | Proportion of students by race, proportion of students eligible for free lunch | 27 (17)
Community characteristics | Proportion by race in census tract, population density, density of food and alcohol establishments, area-level employment, education, income, urban or rural | 38 (24)

BMI=Body Mass Index; n=number of studies; SNAP=Supplemental Nutrition Assistance Program

Among the natural experiment studies, the most common method used to minimize the risk of bias associated with confounding was regression adjustment (73%), followed by direct covariate stratification or matching (12%). Propensity score methods were used in 4 studies (3%). One study used synthetic control methods to create a control group and used that group in models that adjusted for confounding.^108^ In 2004, the Los Angeles school district began regulating the nutritional content of all food in all its schools. Due to the lack of an appropriate comparison group, the researchers created a synthetic control group, which is a weighted combination of several control districts that more closely resembles the Los Angeles school district prior to 2004, in order to evaluate the policy. Although some studies used multiple methods to control for confounding, such as regression adjustment and matched controls, others used very limited or no methods to control for confounding. A challenge in assessing the success of the confounding control, however, is that 33 percent of studies did not include a “Table 1” with a comparison of key demographic and potentially confounding variables (age, sex, race, etc.) between the exposed and unexposed groups.

Instrumental variable, regression discontinuity, and interrupted time series analyses were rarely seen in the studies included in this review. We reviewed fewer than five of each of these studies and cannot generalize risk of bias in these designs due to the small numbers (see KQ 4).

#### Risk of Bias in Experimental Studies

As shown in Figure 9, experimental studies rated strongly in the domains of study design, confounding, and data collection methods, meaning that risk of bias in these domains is low. However, most of these studies were rated as moderate or weak in the areas of blinding, selection bias, and handling of withdrawals and dropouts. In 57 percent of RCTs, the study population was rated very likely to be representative of the target population. Studies also received weak ratings in these categories when they failed to provide the information needed to assess these domains. See Appendix K for individual study risk of bias ratings.

Figure 9 Risk of bias for experimental studies (N= 118)

* Studies are given a “strong” global rating if there are no domains given a “weak” rating, a “moderate” global rating if there is a single domain with a “weak” rating, and a “weak” global rating if there are two or more domains with a “weak” rating.

Figure 9 illustrates the risk of bias assessment of experimental studies. These studies rated strongly in the areas of study design, confounding, and data collection methods. They were rated as moderate or weak in the areas of selection bias, blinding, and withdrawals and dropouts.

#### Risk of Bias in Other Study Designs

As shown in Figure 10, the 20 studies (7%) in this category did not provide sufficient detail to determine whether the research team was in control of the intervention, whether the intervention was originally intended to be research, or otherwise would be included as either a natural experiment or experiment. Sixteen of these studies (80%) received “weak” (i.e., high risk of bias) global ratings using the EPHPP tool. The domains where they were most likely to be rated “weak” included blinding (50% rated weak) and withdrawals and dropouts (65% rated weak). Only 45 percent of the studies described how potential confounders and key demographic information differed between exposed and unexposed groups, making assessments of confounding challenging. These studies did control for some individual confounders such as age (50%) and gender (45%), but none controlled for community level confounders and only 15 percent controlled for school or site level confounders.

Figure 10 Risk of bias for other study designs (N=20)

* Studies are given a “strong” global rating if there are no domains given a “weak” rating, a “moderate” global rating if there is a single domain with a “weak” rating, and a “weak” global rating if there are two or more domains with a “weak” rating.

Figure 10 illustrates the risk of bias assessment of other study designs. Too few studies are included to give overall assessments by domain.

#### Risk of Bias Assessment Using Another Scale

Because no risk of bias tool has been developed specifically for natural experiment studies, we compared our bias assessment from EPHPP with an assessment from the Newcastle-Ottawa Scale^98^ (Appendix L) in a random subsample of 20 natural experiment studies. The domains of the EPHPP and the Newcastle-Ottawa Scale are not directly comparable, and only the EPHPP has a global rating score. The Newcastle-Ottawa scale includes three domains: selection, comparability (of exposed and unexposed groups), and outcome (includes both method of outcome assessment and follow-up rates). As mentioned previously, the EPHPP tool includes the domains of selection bias, study design, confounding, blinding, data collection methods, withdrawals and dropouts, and a global rating. Overall, we showed that fewer natural experiment studies received the highest rating (lowest risk of bias) using the Newcastle-Ottawa Scale, compared with the EPHPP tool. For example, using the Newcastle-Ottawa Scale, only 3 of 20 studies received the highest rating in the “selection” domain, 9 of 20 studies in the “confounding” domain, and one of 20 studies in the “outcomes” domain. Using the EPHPP tool, 5 of 20 received the maximum rating in selection and half received the maximum score in the confounding domain (Appendix L).