# Key Question 4 Experimental and Non-Experimental Methods

## Key Question (KQ) 4 Which experimental and non-experimental methods have been used in studies of how programs, policies, or built environment changes affect or are associated with obesity prevention and control outcomes?

### Overview

While randomized controlled trials (RCTs) and other experimental approaches can provide strong evidence of the effectiveness of some interventions, not all interventions are amenable to randomization. An alternative approach involves use of natural experiment designs, which aim to approximate casual effects by capitalizing on existing variation in an exposure or intervention. Natural experiment studies use a wide range of analytic approaches, which are further described in this section. The goal of KQ 4 was to describe experimental and non-experimental methods in terms of study design and analytic approach.

### Key Findings

- Of the 294 studies included in this review, 156 were natural experiment studies (53%), 118 were experimental studies (40%), and 20 provided insufficient information to determine if a natural experiment took place (7%) and were classified as “other study designs.”
- Natural experiment studies evaluating policies, programs, and built environment changes most commonly used cross-sectional comparisons of exposed and unexposed groups (n=55, 35%).
- Difference-in-differences approaches that compared exposed and unexposed groups before and after an exposure were used in 45 studies (29%), and pre/post designs that compared one group before and after an exposure were used in 48 studies (31%).
- A small number of natural experiment studies in this review used other non-experimental designs including 4 instrumental variable approaches, 1 regression discontinuity approach, and 4 interrupted time series analyses with more than 2 time points pre- and post-intervention.

### Methods

#### Data Abstraction

To address KQ 4, we abstracted details of the natural experiment studies, experimental studies, and other study designs and analytic approaches. After determining whether a study met the UK’s Medical Research Council criteria for a “natural experiment study,” we further classified study designs using the Effective Public Health Practice Project Quality Assessment (EPHPP) tool:^91^ RCT, controlled clinical trial, cohort, case-control, interrupted time series, cross-sectional, and “other”. Definitions of these designs are provided in Appendix B.

Given that some study designs (such as cohort studies) could be used in multiple ways to estimate effects, we further distinguished the analytic approach of each study. While the EPHPP tool collects information regarding the data collection structure, our risk of bias forms additionally focused on the analytic tools used to analyze data. For each study, we classified the analytic approach as an RCT, instrumental variables design, regression discontinuity, interrupted time series, cross-sectional comparison of exposed and unexposed groups, controlled clinical trial, pre/post comparison, difference in differences, or “other” approach.

#### Data Synthesis

We described the types of study designs and analytic methods being used, and their frequency of use, by study design.

### Results

#### Description of Methods Used in Natural Experiment Studies

Over half of the studies (n=156) included in this review met the main criterion for natural experiment studies, based on the MRC Report,^41^ clearly indicating that the researchers were not in control of the exposure allocation (see Methods for KQ4). Eighty-eight of the natural experiment studies took place in community settings (56%) and 49 (31%) were in other institutional settings (e.g., schools or worksites). Nineteen studies (12%) evaluated an intervention or exposure at the level of the individual. Analysis was performed at the individual level in 90 percent of these studies. For example, Project Healthy Schools, a diet and physical activity intervention, was implemented at 23 schools in Michigan, and its success was evaluated by comparing individual changes in body mass index (BMI) and diet among 6^th^ graders before and after the program was implemented.^92^ Most studies evaluating community or school-level programs used methods such as multilevel modeling or robust standard errors to account for the hierarchical structure of the data, but 20 studies (13%) did not account for nested data structure in the analysis.

The most common analytic approach in natural experiment studies was cross-sectional comparisons of exposed and unexposed groups (n=55, 35%). For example, Taber and colleagues used regression models to compare dietary intake among high school students in California, one of the first states to regulate the nutrition content of competitive foods in schools, to students in states without competitive food laws.^93^ The second most common design was pre/post with the pre-intervention period serving as the control for the post-intervention period (n= 48, 31%). For example, one study evaluated changes in physical activity after construction of a bus line and car-free walking and cycling route in Cambridge using a pre/post analysis embedded in an existing cohort study. The study compared activity levels collected from an annual survey one year before and one year after the construction was complete.^55^ Forty-five studies used difference-in-difference approaches (29%) looking at changes before and after the intervention compared to an external control group. This was the third most common study design. This category includes studies such as an evaluation of a new supermarket that opened in a food desert through the Pennsylvania Fresh Food Financing Initiative.^55^ Researchers collected BMI and fruit and vegetable intake from residents of intervention and control neighborhoods at one point before and one point after the construction of the supermarket.

For the 48 pre/post studies, the average number of time points pre- and post-intervention was 1 and 1.6, respectively. For the 45 difference-in-difference studies, which used changes in time and across groups, there were an average of 1 and 1.2 time points pre- and post-intervention. Among the studies included in this review, all pre/post studies measured variables at a single time point pre-intervention, and 80 percent had a single measure post-intervention. Difference-in-difference studies also all had a single measure pre-intervention, and 83 percent had only a single post-intervention measure. We use the terms pre/post and difference-in-difference for studies with multiple time points post-intervention rather than interrupted time series due to the small number of time points (maximum 6 points) and the lack of formal interrupted time series methods such as autoregressive integrated moving average.

#### Description of Methods Used in Experimental Studies

One hundred eighteen studies (40%) included in this review met the criterion for experimental studies, defined as evaluations of researcher-controlled programs, policies, or built environment changes (see Methods for KQ 4). Experimental methods included 74 RCTs (63% of the experimental studies, 25% of all studies), and 44 controlled trials (37% of experimental studies, 15% of all studies) in which the investigator assigned the exposure by means other than randomization (Table 10). Shape Up Somerville is an example of a controlled clinical trial that took place in one intervention and two control communities in Massachusetts. Researchers selected Somerville as the intervention site due to ongoing relationships with that community, so this would not be considered a natural experiment. This community-wide, multi-level diet and physical activity program included a Walk to School Campaign, changes to school breakfast and lunch programs, school and afterschool education programming, enhanced playgrounds for recess, and a restaurant initiative.^94^

Table 10 Overview of study design or data collection structure (N=294 studies)

| n | Percent
Natural experiment^*^ studies | 156 | 53
Cross-sectional comparison of exposed and unexposed groups | 55 | 35
Pre/Post | 48 | 31
Difference-in-differences | 45 | 29
Regression Discontinuity | 1 | 1
Interrupted Time Series | 4 | 3
Instrumental Variables | 4 | 3
Other | 1 | 1
Experimental studies | 118 | 40
RCT | 74 | 63
CCT | 44 | 37
Other studies | 20 | 7
Regression model | 3 | 15
Pre/Post | 9 | 45
Difference-in-differences | 8 | 40

* Studies may employ multiple methods and therefore be counted in several categories.

Of the experimental studies, the unit of intervention allocation was most often at the organization level (66%) or the community level (23%). Analyses were most often conducted at the individual level (93%).

#### Description of Methods Used in Other Study Approaches

Twenty studies in this category (7%) did not provide sufficient detail to determine whether the research team was in control of assigning the intervention, whether the intervention was originally intended to be research, or otherwise would be included as either a natural experiment or experiment. Most often, the exposure was at the community (40%) or organizational (45%) level, but the analysis was carried out at the individual level (90% of studies). Thirty-five percent of these studies did not take the hierarchical nature of the data structure into account in the analysis. These studies were most often pre/post (45%) or difference-in–differences (40%) designs.