# Key Question 3 Assessment Measures

## Key Question (KQ) 3 What obesity measures, dietary and physical activity behaviors, and other outcomes have been assessed in studies of how programs, policies, or built environment changes affect or are associated with obesity prevention and control?

### Overview

The goal of KQ 3 was to describe and synthesize what obesity, dietary and physical activity measures were used to assess childhood and adult obesity outcomes, dietary and physical activity behaviors, and other co-outcomes (e.g., commuting behavior). For each measure, we described the type of measure (e.g., the name of the questionnaire used to assess fruit and vegetable intake), how the data was collected (e.g., trained study staff for height/weight vs. self-reported questionnaires) and the data source that contained the measure when it was obtained from a secondary data source. We presented the results by population (children and adults) and study design (natural experiment, experimental, other study design).

### Key Findings

- One hundred twelve studies out of 294 (38%) reported on childhood weight outcomes, primarily body mass index (BMI) z-score or BMI percentile. Most studies reporting childhood weight outcomes assessed the outcomes using direct measurement from trained staff.
- Thirty-two studies reported adult weight outcomes and these were mostly conducted in community or worksite settings.
- One hundred forty-eight studies reported dietary behavioral outcomes in terms of change in the intake of fruits and vegetables (n=147), sugar-sweetened beverages (n=54), total daily caloric intake (n=17), fast food intake (n=16), and fiber (n=12).
- One hundred fifty-two studies reported physical activity measures. Most studies reporting physical activity outcomes took place in school (n=89) or community (n=40) settings.

### Methods

#### Data Abstraction

We abstracted detailed information about which of the following obesity measures, dietary or physical activity behavioral measure and other co-outcomes were reported in the studies:

- Adult body weight and BMI
- Childhood BMI (z-score and percentile)
- Individual dietary intake and behaviors. We included measure of total daily caloric intake; specific macronutrients related to obesity (including vegetable, fruit, or fiber intake); sugar-sweetened beverage intake; or fast food intake.
- Individual physical activity behavior, in terms of both activity type and quantity
- Co-outcomes: food environment, physical activity environment, other outcomes (e.g., housing, economic)

We abstracted which measures and/or questionnaires were used to assess the outcomes and which of the data sources from KQ1 contained the measures.

#### Data Synthesis

We counted the number of studies that reported each outcome and categories of outcomes of interest. We described the types of measures or instruments used to assess these outcomes, based on categories from the National Collaboration on Childhood Obesity Research Measures Registry.^53^ Definitions of these categories are provided in Appendix B. The data sources and questionnaires used for these measures were also reported and described. We stratified this section by study design: natural experiment studies, experimental studies, and other study designs.

### Results

We identified 112 studies reporting on childhood weight outcomes, 32 studies on adult weight outcomes, 152 studies on physical activity outcomes, and 148 studies on dietary outcomes. Forty-seven studies reported both diet and physical activity outcomes. Thirty-seven studies reported on co-outcomes, such as commuting behaviors, food environment, physical environment, and food purchasing behavior (see Appendix H, Evidence Tables H3–H15).

#### Obesity Measures: Weight and BMI in Children and Adults

Table 6 displays the obesity measures used to assess weight and BMI in adults and children. For children, 112 studies reported body weight, BMI percentile, and/or BMI-z score in children: 57 in terms of BMI z-score, 46 in terms of BMI percentile change, and 27 with other childhood weight outcomes. For adults, 32 studies reported body weight in adults: 31 in terms of BMI and 6 in terms of weight change.

Table 6 Weight outcomes and measures in adults and children, by study design

| | Measure, n (%)^*^
Method and Population | Outcome | Measured by Trained Staff | EHR | Self-Reported | Other
Natural Experiment Studies
Children 50 studies | Change in BMI z-score | 14 (60.9) | 1 (4.3) | 3 (13) | 5 (21.8)
Children 50 studies | Change in BMI percentile | 15 (55.6) | 0 | 6 (22.2) | 6 (22.2)
Children 50 studies | Change in weight | 7 (87.5) | 0 | 0 | 1 (12.5)
Adult 17 studies | Change in body weight | 0 | 0 | 1 (100) | 0
Adult 17 studies | Change in BMI | 6 (37.5) | 0 | 10 (62.5) | 0
Experimental Studies
Children 48 studies | Change in BMI z-score | 27 (84.4) | 0 | 2 (6.3) | 3 (9.4)
Children 48 studies | Change in BMI percentile | 13 (76.5) | 1 (5.9) | 2 (11.8) | 1 (5.9)
Children 48 studies | Change in weight | 7 (77.8) | 0 | 0 | 2 (22.2)
Adult 13 studies | Change in body weight | 5 (100) | 0 | 0 | 0
Adult 13 studies | Change in BMI | 7 (53.8) | 0 | 6 (46.2) | 0
Other Study Designs
Children 6 studies | Change in BMI z-score | 3 (100) | 0 | 0 | 0
Children 6 studies | Change in BMI percentile | 3 (100) | 0 | 0 | 0
Children 6 studies | Change in weight | 1 (100) | 0 | 0 | 0
Adult 2 studies | Change in body weight | 0 | 0 | 0 | 0
Adult 2 studies | Change in BMI | 0 | 0 | 1 (50) | 1 (50)

* Many studies included more than one type of weight measure or weight outcome.

BMI=Body Mass Index; BMI-z=Body Mass Index z-score; EHR=electronic health records; n=number of measures reported;

##### BMI Measures in Children

Of the 95 studies reporting weight or BMI in children, 46 were natural experiment studies, 44 were experimental studies (randomized controlled trials (RCTs) and controlled clinical trials), and 5 were classified as “other study designs” (see Methods for definitions of study designs). Fifty-seven studies reported BMI z-score and 46 reported on BMI percentile. Most studies reporting weight measures in children were conducted in a school setting (n=88).

##### Natural Experiment Studies Reporting BMI in Children

Of the 46 natural experiment studies reporting data on BMI z-score or BMI percentile in children, 25 studies reported the outcome based on direct measurement from trained staff, one study used an EHR, 8 studies used self-reported data, and 8 studies used other measures (e.g., FitnessGram assessment). Out of the total reported measures, natural experiment studies commonly reported using trained staff to measure BMI in children (BMI percentile: 55.6 percent, BMI-z score: 60.9%) (Table 6, Appendix H, Evidence Tables H3–H4)

Evidence Table H16 in Appendix H displays details about U.S. secondary data sources containing each of the weight measures, by study design (natural experiment, experimental, other design). Natural experiment studies used 26 different U.S. data sources for childhood weight measures, including the National Survey of Children’s Health, Early Childhood Longitudinal Study-Kindergarten Cohort, and School Health Policies and Programs Study (Appendix H, Evidence Table H16).

##### Experimental Studies Reporting BMI in Children

Of the 39 experimental studies reporting on children’s BMI-z or BMI percentile, 33 studies reported the outcome based on direct measurement from trained staff, 1 study used an EHR, 3 studies used self-reported data, and 3 studies used other measures (i.e., body composition analyzer). Out of total reported measures, experimental studies commonly reported using trained staff to measure BMI in children (BMI percentile: 76.5%, BMI-z score: 84.4%) (Table 6; Appendix H, Evidence Tables H3–H4).

##### Other Weight Outcomes in Children

Twenty-five studies either directly captured child weight (n=17) or reported other weight outcome measurements (n=8). Of the 17 studies reporting child weight, 8 were natural experiment studies and 9 were other experimental methods. All but three studies reported outcomes based on direct measurement by trained staff (Table 6).

Eight studies reported other child weight outcomes not designated in our populations, interventions, comparators, outcomes, timing, setting framework. These included BMI (not BMI-z score or BMI percentile), rates of BMI change in participants, and probability of obesity (see Appendix H, Evidence Tables H5–H6).

##### Weight and BMI in Adults

Thirty-two studies reported on adult body weight and BMI outcomes. Thirty-one studies reported on change in adult BMI, and 6 studies reported on change in adult weight. Most studies reporting weight measures in adults were conducted in community (n=15) or worksite (n=10) settings. Seventeen studies reporting adult weight or BMI were natural experiment studies, 13 were experimental studies, and 2 were other study designs.

##### Natural Experiment Studies Reporting Weight or BMI in Adults

Of the 17 natural experiment studies reporting data on change in body weight or BMI, 6 studies reported this outcome based on direct measurement from trained staff and 11 studies used self-reported data. None of the studies used an electronic health record (EHR) for weight or BMI measures in adults.

Evidence Table H16 in Appendix H shows details about U.S. secondary data sources containing each of the weight measures, by study design (natural experiment, experimental, other design). Natural experiment studies used 12 different U.S. data sources for adult weight and BMI measures, including the Behavioral Risk Factor Surveillance System (BRFSS) and the L.A. County Food Retail database. (Appendix H, Evidence Table H17).

##### Experimental Studies Reporting Weight or BMI in Adults

Of the 13 experimental studies reporting data on change in body weight or BMI, 9 studies reported the outcome based on direct measurement from trained staff (BMI: n=7; weight: n=2), no studies used an EHR, and 6 studies used self-reported data (BMI: n=6).

#### Measures of Dietary Behaviors in Adults and Children

One hundred forty-eight studies reported dietary behavioral outcomes in terms of change in the intake of fruits and vegetables (n=147), sugar-sweetened beverages (n=54), total daily caloric intake (n=17), fast food intake (n=16), and fiber (n=12). Most studies reporting dietary behavioral outcomes conducted their study within the school (n=86) or community (n=42) setting. In general, studies used measures to assess only some key aspect of these dietary behaviors rather than the total diet comprehensively, such as through repeated 24-hour recalls or food frequency questionnaires (for definitions, see Appendix B). For example, the Pittsburgh Hill/Homewood Research on Eating, Shopping and Health^21^ was a natural experiment that examined the effect of a full-service supermarket on diet and other outcomes using the 24-hour recall. The Norwegian School Fruit Program^23^ study was an experimental study that evaluated a fruit and vegetable program in schools, also using the 24-hour recall.

Table 7 shows the dietary measures used in studies of children and adults by study design. Overall, 77 studies were natural experiment studies, 63 were experimental studies, and 11 were other study designs (several studies collected adult and child data). Among the 107 studies in children, 95 studies reported on intake of fruits and vegetables, 45 on sugar-sweetened beverages, 11 on total calories, 12 on fast food, and 9 on fiber. Among the 50 studies in adults, 43 studies reported on intake of fruits and vegetables, 11 on sugar-sweetened beverages, 6 on total calories, 5 on fast food, and 3 on fiber.

Table 7 Dietary outcomes and measures for children and adults, by study design

Method and Population | Outcome | 24-Recall, n (%) | FFQ, n (%) | Questionnaire, n (%) | Record/Log, n (%) | Observation, n (%) | Other, n (%)
Natural Experiment Studies
Children 52 studies | Caloric intake | 3 (50) | 1 (16.7) | 0 | 2 (33.3) | 0 | 0
Children 52 studies | Fast food | 1 (14.3) | 1 (14.3) | 4 (57.1) | 1 (14.3) | 0 | 0
Children 52 studies | SSB | 1 (4.8) | 2 (9.5) | 16 (76.2) | 2 (9.5) | 0 | 0
Children 52 studies | Fruit/veg | 5 (11.6) | 6 (14) | 29 (67.4) | 3 (7) | 0 | 0
Children 52 studies | Fiber | 1 (20) | 0 | 2 (40) | 2 (40) | 0 | 0
Adult 30 studies | Caloric intake | 2 (66.6) | 0 | 0 | 1 (33.3) | 0 | 0
Adult 30 studies | Fast food | 0 | 1 (25) | 3 (75) | 0 | 0 | 0
Adult 30 studies | SSB | 1 (10) | 3 (30) | 5 (50) | 1 (10) | 0 | 0
Adult 30 studies | Fruit/veg | 5 (15.6) | 10 (331.3) | 14 (43.8) | 3 (9.4) | 0 | 0
Adult 30 studies | Fiber | 0 | 0 | 0 | 1 (100) | 0 | 0
Experimental Studies
Children 47 studies | Caloric intake | 0 | 1 (20) | 1 (20) | 1 (20) | 1 (20) | 1 (20)
Children 47 studies | Fast food | 1 (25) | 0 | 3 (75) | 0 | 0 | 0
Children 47 studies | SSB | 4 (18.2) | 7 (31.8) | 9 (40.9) | 0 | 1 (4.5) | 1 (4.5)
Children 47 studies | Fruit/veg | 12 (23.1) | 15(28.8) | 14 (26.9) | 1 (1.9) | 5 (9.6) | 5 (9.6)
Children 47 studies | Fiber | 0 | 3 (75) | 1 (25) | 0 | 0 | 0
Adult 17 studies | Caloric intake | 1 (50) | 0 | 0 | 0 | 0 | 1 (50)
Adult 17 studies | Fast food | 0 | 1 (100) | 0 | 0 | 0 | 0
Adult 17 studies | Sugar sweetened beverage | 0 | 1 (100) | 0 | 0 | 0 | 0
Adult 17 studies | Fruit/veg | 0 | 7 (46.7) | 5 (33.3) | 1 (6.7) | 0 | 2 (13.3)
Adult 17 studies | Fiber | 0 | 1 (50) | 1 (50) | 0 | 0 | 0
Other Study Designs
Children 8 studies | Caloric intake | 0 | 0 | 0 | 0 | 0 | 0
Children 8 studies | Fast food | 0 | 0 | 1 (100) | 0 | 0 | 0
Children 8 studies | SSB | 1 (20) | 2 (40) | 2 (40) | 0 | 0 | 0
Children 8 studies | Fruit/veg | 2 (25) | 2 (25) | 4 (50) | 0 | 0 | 0
Children 8 studies | Fiber | 0 | 0 | 0 | 0 | 0 | 0
Adult 3 studies | Caloric intake | 0 | 0 | 0 | 0 | 0 | 0
Adult 3 studies | Fast food | 0 | 0 | 0 | 0 | 0 | 0
Adult 3 studies | SSB | 0 | 0 | 0 | 0 | 0 | 0
Adult 3 studies | Fruit/veg | 0 | 2 (66.6) | 1 (33.3) | 0 | 0 | 0
Adult 3 studies | Fiber | 0 | 0 | 0 | 0 | 0 | 0

Many studies included more than one type of diet measure or diet outcome.

FFQ=food frequency questionnaire; Fruit/veg=fruit and vegetables; n=number of measures reported; N=number of studies; SSB=sugar sweetened beverage

##### Dietary Behaviors in Children

Table 7 shows the methods for assessing dietary behaviors in children. The most commonly used method for assessing diet was through brief dietary questionnaires (e.g., The Boston Youth Survey). Of the 52 natural experiment studies reporting data on diet in children, 6 studies used a 24-hour recall, 7 studies used a food frequency questionnaire, 34 studies used other questionnaires, and 5 used a record/log.

Evidence Table H16 in Appendix H provides details about U.S. secondary data sources containing each of the dietary measures, by study design (natural experiment, experimental, other design). In U.S. studies in children, the natural experimental studies used data sources with dietary measures such as the National Survey of Children’s Health and the National Youth Physical Activity and Nutrition Study (Appendix H, Evidence Table H16).

Among the natural experiment studies, commonly used questionnaires that assessed dietary behaviors in children included the School Physical Activity and Nutrition (SPAN) Questionnaire, Youth Risk Behavior Survey (YRBS) Questionnaire, and the Boston Youth Survey.

Of the 47 experimental studies (RCTs and non-randomized controlled trials) reporting on children’s diet, 12 reported the outcome based on 24-hour recall, 17 used a food frequency questionnaire, 15 used other questionnaires, one used a record/log, 5 used observation, and 7 used other measures (i.e., structured interviews, digital images).

Experimental studies used questionnaires such as The Child and Adolescent Trial for Cardiovascular Health After-School Student Questionnaire (ASSQ) (Appendix H, Evidence Table H17).

##### Dietary Behaviors in Adults

Table 7 shows the methods for assessing dietary behaviors in adults. The most commonly used method for assessing diet was through food frequency or brief dietary questionnaires such as the National Health and Nutrition Examination Survey, as well as internally designed questionnaires (Table 7). Of the 30 natural experiment studies reporting measures of dietary behaviors in adults, 4 used a 24-hour recall, 10 used a food frequency questionnaire, 18 used other questionnaires, 3 used a record/log, and none used observation.

Evidence Table H16 displays details about U.S. secondary data sources containing each of the dietary measures, by study design (natural experiment, experimental, other study design).

Among the U.S. studies in adults, the most frequently used data source reporting adult diet behavioral measures was the brief diet screener of the BRFSS, which was used in four natural experiment studies. Both experimental and other study designs used primary data collection as their source (Appendix H, Evidence Table H16). Examples of questionnaires used by experimental and other study designs are the Customer Impact Questionnaire and the Five-a-day Community Evaluation Tool, respectively (Table 8).

Table 8 Physical activity outcomes and measures, by study design

Method and Population | Electronic Monitor, n (%) | Questionnaire, n (%) | Record/Log, n (%) | Observation, n (%) | GIS, n (%) | Other, n (%)
Natural Experiment Studies
Children 43 studies | 17 (32.7) | 27 (51.9) | 1 (1.9) | 4 (7.7) | 0 | 3 (5.8)
Adult 32 studies | 6 (13) | 35 (76.1) | 2 (4.3) | 1 (2.2) | 0 | 2 (4.3)
Experimental Studies
Children 53 studies | 22 (33.8) | 21 (32.3) | 6 (9.2) | 6 (9.2) | 0 | 10 (15.4)
Adult 13 studies | 3 (20) | 10 (66.7) | 1 (6.7) | 1 (6.7) | 0 | 0
Other Study Designs
Children 10 studies | 3 (27.2) | 5 (45.5) | 0 | 0 | 0 | 3 (27.2)
Adult 5 studies | 1 (12.5) | 5 (62.5) | 1 (12.5) | 0 | 0 | 1 (12.5)

* Many studies included more than one type of physical activity measure.

GIS=Geographic Information System; n=number of measures reported; N=number of studies

Of the 17 experimental studies (RCTs and non-randomized controlled trials) reporting data on diet, one reported the outcome based on 24-hour recall, 7 used a food frequency questionnaire, 6 used other questionnaires, one used a record/log, none used observation, and 4 used other measures.

#### Measures of Physical Activity in Adults and Children

One hundred fifty-two studies reported physical activity measures. Most studies reporting physical activity outcomes took place in school (n=89) or community (n=40) settings. All 42 of the studies with a goal of changing the parks and recreation, or transportation environment, measured physical activity. In general, studies used measures to assess only some key aspect of physical activity behavior rather than total physical activity comprehensively.

An example is the use of a pedometer to count steps as a proxy measurement of physical activity. Studies that used this type of measure include the Great Fun 2 Run study,^89^ which is a natural experiment looking at increasing physical activity levels in schools through physical education lessons. Another example is the Healthy Schools Project,^90^ which uses an experimental method to observe if augmented recess sessions increase physical activity over standard sessions.

Table 8 shows the physical activity measures in studies of children and adults by study design. Overall, 71 studies were natural experiment studies, 66 were experimental studies, and 15 were other study designs.

##### Measures of Physical Activity in Children

In children, the most commonly used methods for assessing physical activity were questionnaires (n=46) and electronic monitoring (n=32) (Table 8). Of the 43 natural experiment studies reporting data on physical activity in children, 16 measured physical activity using electronic monitoring (accelerometer n=13, pedometer n=2, telemeter n=2, global positioning system (GPS) n=1), 25 used a questionnaire, one used a record/log, 4 used observation, and 3 used other measures.

U.S. studies varied considerably in the physical activity questionnaires used with children in natural experiment studies. Examples included the SPAN Questionnaire and the National Youth Risk Behavior Survey among many others. The International Physical Activity Questionnaire was the most used questionnaire (n=3), followed by the YRBS) Questionnaire (n=2). The first publication describing the use of electronic monitoring in natural experiment studies with children was in 2005 and use of such monitoring peaked in 2014 (n=7).

Evidence Table H16 in Appendix H shows details about U.S. secondary data sources containing each of the physical activity measures, by study design (natural experiment, experimental, other design). In U.S. studies conducted in children, natural experiment studies most commonly used data sources such as the Physical Education-Related State Policy Classification System, Family Activity Study (FAS) data, or the School Nutrition-Environment State Policy Classification. (Appendix H, Evidence Table H16).

Of the 53 experimental studies reporting on children’s physical activity, 22 used electronic monitoring (accelerometer n=13, pedometer n=7, motion sensor n=1, telemetry n=1), 21 used a questionnaire (i.e., Test of Gross Movement Development), 6 used a record/log, 6 used observation, none used geographic information systems, and 10 used other measures (i.e., Chinese National Measurement Standards on People’s Physical Fitness). (Table 8)

Experimental studies in the U.S. in children used tools such as the Self-Administered Physical Activity Checklist and the Test of Gross Movement Development checklist. No questionnaire was used in more than one study. Eight of the questionnaires were self-reported, 3 were recorded by parents or teachers, and the reporting participant in 7 questionnaires could not be determined (Appendix H, Evidence Table H17). The use of electronic monitoring in experimental studies involving children began in 2003 and peaked in 2015 (n=5).

##### Measures of Physical Activity in Adults

In adults, the most commonly used method for assessing physical activity was through questionnaires (n=40) (Table 8). Of the 32 natural experiment studies reporting data on physical activity in adults, 5 reported the outcome based on electronic monitoring (accelerometer n=4, GPS n=1, unreported n=1), 24 used a questionnaire, 2 used a record/log, one used observation, and 2 used other measures (e.g., Compendium of Physical Activities metabolic equivalent of task values).

Data sources with measures of physical activity in U.S. studies of adults using natural experiment studies include the FAS, National Household Travel Survey, and the Trip Identification and Analysis System (Appendix H, Evidence Table H16). The most frequently used questionnaires to assess physical activity were the International Physical Activity Questionnaire (n=3) and BRFSS (n=2) for the natural experimental studies conducted in U.S. adult populations (Table 8). Studies using electronic monitoring in natural experiments with adults were first published in 2014 (n=2), and use has remained low.

Of the 12 experimental studies (RCTs and non-randomized controlled trials) reporting on physical activity in adults, 3 used electronic monitoring (accelerometer n=2, laser counter n=1), 10 used a questionnaire (i.e., International Physical Activity Questionnaire), one used a record/log, one used observation, and none used geographic information system or other measures (Table 8). Experimental studies in the United States used measures such as the Godin Leisure Time Physical Activity Questionnaire (Appendix H, Evidence Table H17). Few experimental studies in adults used electronic monitoring and the first ones were published in 2012 (n=2).

#### Other Co-Outcomes

Thirty-seven studies reported on co-outcomes such as commuting behavior, food purchasing behavior, physical environment, and food environment (see Table 9). Overall, most (n=26) of the studies reporting co-outcomes were natural experiment studies. The most common co-outcome was food purchasing behavior (n=17) (e.g., purchasing of healthy and unhealthy food score). Four studies reported on commuting behavior (e.g., average daily commute mode of transport). 6 studies reported on the food environment (e.g., school-reported soda availability), and 8 studies evaluated the physical activity environment (e.g., neighborhood characteristics to facilitate walking).

Table 9 Summary of the distribution of co-outcomes among study designs (N=37 studies)

Co-Outcome | n
Natural Experiment Studies
Commuting behavior | 3
Food environment | 3
Physical activity environment | 4
Physical or built environment | 0
Food purchasing behavior | 12
Other | 3
Experimental Studies
Commuting behavior | 1
Food environment | 3
Physical activity environment | 2
Physical or built environment | 0
Food purchasing behavior | 5
Other | 1
Other Study Designs
Commuting behavior | 0
Food environment | 0
Physical activity environment | 1
Physical or built environment | 0
Food purchasing behavior | 0
Other | 0

N=number of studies