# Key Question 2 Linking Data Sources

## Key Question (KQ) 2 What methods have been used to link different population-based data sources?

### Overview

Policy makers have expressed increasing interest in linking population-based data sources to address questions about the effectiveness of policies and programs in obesity prevention and control. The goal of KQ2 was to assess and describe data linkages between data systems identified in KQ1.

### Key Findings

- 26 (37%) of the 71 U.S. data systems were linked with a secondary data source or system other than the primary data sources for the purposes of the research study.
- Studies that linked their data systems with multiple external data systems either used an individual-level key (14%; e.g., patient identifiers) or a geographic allocation (23%; e.g., patient resides in a specific county thus mapping the county specifications extracted from other data sources for that individual).
- One study used statistical models to link primary data sources with external data sources and adjust for potential covariates.

### Methods

#### Data Abstraction

For each U.S. data system identified in KQ 1, we assessed whether and how the data systems have been linked together, using information obtained from the study and, as described above, using publicly available information. The coding schema (see Appendix E) included a series of coding items to identify how the identified studies linked data sources together.

### Results

For KQ 2 we qualitatively described the methods used to link these data systems (see KQ2 data abstraction). We aggregated and summarized the data across various coding schema attributes. The summary report includes various data system attributes across the entire list of data systems and is accompanied with notations about which data specifications (e.g., linkage methods) were found to be effective and which ones have faced challenges.

Of the 71 U.S. data systems reported in KQ 1, 26 data systems (37%) linked their data system with another data source. These data sources were linked for the purposes of the research study and had not been previously linked. All 26 data systems occurred in natural experiment studies.

Ten (14%) of the 71 U.S. data systems used an individual-level linkage. Most of the survey-based studies used existing data from other surveys to locate potential participants and import already captured data about those participants in their study. Examples of these external surveys that were used for individual-level linkage include: Women, Infants, and Children, Supplemental Nutrition Assistance Program, Common Core Data, Early Childhood Longitudinal Study-Kindergarten, The Military Teenagers’ Environments, Exercise, and Nutrition Study, and vital records.

Sixteen (23%) of the 71 U.S. data systems used a geographical-level linkage to capture additional data about their denominator of participants. These added variables were eventually used as direct, indirect, or adjustment variables for the studies. Most of the studies using a geographical-level linkage used a simple geographical name match (e.g., zip code match), but two used more advanced methods (e.g., locating an address within a geographical boundary). Examples of the external geographical data systems they linked to included: U.S. Census, Dun and Bradstreet, National Household Travel Survey, Trip Identification and Analysis System, and local, state or national maps for food retails, property and sales taxes, and crime rates. Two studies used statistical models (i.e., regression models) to link a primary data source with external geographical data sources to adjust for potential confounders in the statistical models. Regression models are considered a standard approach.^88^