# Key Question 1 Population-Based Data Sources

## Key Question (KQ) 1 What population-based data sources have been used in studies of how programs, policies, or built environment changes affect or are associated with obesity prevention and control outcomes?

### Overview

To improve our understanding of which population-based data sources have been used in obesity prevention and control studies, KQ1 identified all data sources and encoded them based on whether they meet criteria to be a data system (i.e., most usable for obesity researchers), their original purpose and outcomes they contained.

### Key Findings

- 294 studies reported one or more population-based data sources. The majority (216 of 294) of the U.S. and non-U.S. studies included some primary data collection and most of these 216 primary data sources were not sharable (e.g., did not have a public or transferable license to allow data to be used for research purposes).
- 93 U.S. and non-U.S. studies included secondary and/or sharable primary data sources.
- Of these 93 studies, we identified 143 secondary data sources and 26 sharable primary data sources (totaling 116 data sources after duplicates were removed).
- Of the 116 data sources, 106 (71 U.S. and 35 non-U.S. data systems) met the four criteria for data system (data source exists, is available for research, is sharable and contains outcomes or co-outcomes of interest).
- 96 of the 106 data systems were used in natural experiment studies, 7 were used in experimental studies, and 3 were used in studies with other study designs.
- Among the 71 U.S. data systems, 28 (39%) were originally designed for administrative purposes and 22 (31%) for public health operations. More than half of the 71 U.S. data systems had national coverage (57%).
- 44 (62%) of the 71 U.S. data systems contained at least one of the main outcomes of weight or BMI or dietary or physical activity behaviors, while 40 data systems (53%) included at least one of the co-outcomes or exposures, such as information about the policy, program, built environment, or other geographical information.

### Methods

#### Data Abstraction

We abstracted and generated a list of all data sources reported in included studies. We identified each data source (U.S. and non-U.S.), with all duplicate data sources removed, and provided a count of the number of studies that used each data source. A primary data source was defined as one primarily collected for the purpose of a study (e.g., collecting survey data from participants to test the hypothesis of a study). If the data of a primary data source was being shared with other researchers, in any form including a public use dataset, we considered it to be a sharable primary data source.

We used this list of data sources to apply a set of criteria (Table 5) to determine if a data source is a data system that is actively maintained, can be acquired or accessed by researchers, and contains the outcomes of interest. The ‘data system’ criteria (Table 5) were developed for a previous project that our team conducted for the Pathways to Prevention program focused on data sources used to evaluate suicide prevention programs.^86^ A data system represents one or more organized and accessible data sources that go beyond just collecting and managing data, but also contain some degree of an information technology infrastructure to maintain and operate the system. We applied these criteria to data sources identified in KQ 1 to inform obesity researchers not only about which data sources have been used in prior studies, but also what data sources are still available and can be used by researchers (i.e., meeting the data system criteria), which are key characteristics that make these data systems useful for future research.

Table 5 Criteria to determine whether a data source meets the criteria of a data system related to obesity

1 Data source is still in existence (e.g., information about the data system can be found on the Web)
2 Data are available and accessible in digital format (e.g., datasets are downloadable from a current Web site)
3 Data are sharable and can be acquired by others for research purposes (e.g., has a public or transferable license that allows the data to be used for research purposes)
4 Data system collects/contains at least one of the outcomes of interest (e.g., primary outcomes, such as weight and height, or secondary outcomes, such as policy and built environment)

Data sources not meeting the data system criteria (Table 5) were not further coded as they were deemed impractical for research (e.g., the data source does not exist anymore, or it cannot be shared with other researchers). Data sources meeting the data system criteria (Table 5; referred to as ‘data systems’) were further coded based on information collected from the studies and information found on the Web. NonU.S. data systems were coded in a limited manner due to language barriers and other issues with data access. U.S. data systems were further coded according to a coding and classification schema that was adapted and modified from a framework previously developed to review and evaluate community-based data sources (Appendix E).^87^ These data coding schema include items such as data granularity (population- or individual-level), denominator coverage, data collection method, data scalability, data governance, data uses and functions, and data linkage mechanisms (see KQ2). To complete the data coding schema for each of the identified U.S. data systems, we located and accessed publicly available information (e.g., data dictionaries) of the data systems after we obtained as much information as possible from the studies. We did not download and analyze the data systems, as that was out of the scope of this review (e.g., conducting statistical analyses of the data systems to compute data quality measures).

#### Data Synthesis

We encoded each of the U.S. data systems identified in the studies using the coding schema (Appendix E). This process produced a list and description of all data systems, the categories of variables they contain, and various data specifications as described in the coding schema. The coding schema included a number of coding items grouped in various categories such as: data system specification and meta-data; geographical coverage (e.g., country, state, community); demographic coverage; data granularity; variables and outcomes of interest; data system scalability; and data system governance. See Appendix E for the detailed list of items used to encode the U.S. data systems.

### Results

#### Identification of Data Sources and Data Systems

Of 294 included studies, all reported at least one data source (Figure 3). We identified 216 studies with at least one data source from primary data collection performed for that study. A primary data source was defined as one primarily collected for the purpose of a study (e.g., collecting survey data from participants to test the hypothesis of a study). Primary data sources were used by the researchers to conduct the project but were not made sharable for other researchers (e.g., has a public or transferable license that allows the data to be used for research purposes). Non-sharable primary data sources were excluded from the next steps of the data source abstraction, as by definition, they did not qualify as a data system (e.g., are not sharable; see Table 5). See Appendix B for definition of data system.

Figure 3 Identification and classification of data sources and systems in included studies

Figure 3 depicts the flow of included studies through the evaluation of data systems. Ninty-three studies included 106 unique, sharable primary or secondary data sources. Seventy-one were US data sources, 26 were linked to other data sources: 10 on an individual level; 16 using geopgraphy.

If the data of a primary data source was being shared with other researchers, in any form including a public use dataset, we considered it to be sharable primary data source. Ninety-three studies contained a total of 169 data sources that were sharable, of which 26 were sharable primary data collection sources and 143 were secondary data sources. We defined secondary data sources as those used in the studies but not directly collected by the study researchers (i.e., data source was external to the study). After removing the duplicates (n=53) and data sources that did not meet all data system criteria (n=10) (data source exists, is available for research, is sharable and contains outcomes or co-outcomes of interest) (Table 5), 106 unique data systems (71 U.S. and 35 non-U.S.) were identified for the final review and detailed coding (Appendix J). Appendix J lists all the data sources that met criteria for a data system (data source exists, is available for research, is sharable and contains outcomes or co-outcomes of interest) reported in the included studies, stratified by U.S. and non-U.S. data studies, and by natural experiment studies, experimental studies, and studies with other study designs (see Appendix J). These 106 unique data systems included 20 sharable primary data sources and 86 secondary data sources (Figure 3). Of the 106 data systems, 96 of the data systems were used in natural experiment studies, 7 were used in experimental studies, and 3 were used in studies with other study designs.

The 71 U.S. data systems underwent detailed coding to characterize the level of information available (see KQ 1 Methods and Appendix E) and were used as the denominator for all results reported in this section. Figure 4 shows results of the coding. Most of the 71 U.S. data systems had a dedicated Web page (73%), but most of these Web pages only included high-level summaries or limited details about the data systems (32%). Only 19 percent of the Web pages about the data systems included highly detailed information, such as data quality (e.g., completeness, accuracy, and timeliness of the data). For example, the National Health and Nutrition Examination Survey– maintained by the CDC – provides detailed information about data quality issues and potential analytical pitfalls if data are not used properly.

Figure 4 Level of information available for U.S. data systems (n=71)

Note: Values in each group that are depicted by the lighter color are mutually exclusive

Figure 4 graphically illustrates the level of information available in U.S. Data systems by identifying whether a data dictionary is available, whether the data is accessible, and whether the data is stored or collected on a dedicated web page.

More than half of the 71 U.S. data systems (59%) were available for download but some (about 14%) required a form of registration or permission before accessing the data. Although 70 percent of the data systems had some level of information about their data structure (e.g., survey questionnaires, summary reports), only 15 percent of them presented a formal data dictionary on their Web pages (e.g., auto generated code books reflecting the database structure, variables, ranges, and definitions). Most data systems used unconventional documentation (i.e., not a data dictionary) to inform the users about their data structure and variables. For example, 25 percent provided only informal documentation about their data structure (which did not qualify as a data dictionary), and 29 percent offered survey instruments and other documentation that could be used to infer data structure and variables.

Figure 5 shows the original purpose for data use and function for the 71 U.S. data systems. Most of the data systems were designed for administrative purposes (39%) or public health operations such as surveillance (31%). About 29 percent of the data systems identified were primarily developed and maintained for research purposes. Only about 2 percent of the data systems were originally developed and maintained for clinical care purposes.

Figure 5 Original purpose for data use and function for U.S. data systems (n=71)

Figure 5 identifies the original purpose of data use in U.S. Data systems: public health (31.0%), research (29.6%), administrative (39.4 %), and clinical (1.6%).

Figure 6 displays the demographic coverage of the 63 U.S. data systems. Fifteen (21%) of the U.S. data systems have the general population as their denominator. Most of the data systems focused on schools (n=26), communities (n=16), or other specific programs (n=5). Most of the data systems included data on school-age children: 22 (31%) in elementary schools, 26 (37%) in middle schools, and 23 (32%) in high schools. Fewer than 21 percent of the U.S. data systems focused on the adult population. None of the data systems were designed to capture outcomes of interest for older adults or other special populations. Socio-economic status was captured in 20 (28%) data systems. Race and ethnicity variables were available in 24 (34%) and 22 (31%) data systems, respectively.

Figure 6 Demographic coverage of U.S. data systems (n=71)

Note: Values in each group are not mutually exclusive and do not sum up to 100 percent, as a data system may cover multiple groups.

Figure 6 graphically ilustrates the demographic coverage of U.S. Data systems by age coverage (infant through adult); population denominator (general population, community level, schools, programs, households, other), and other demographics (race, ethnicity, and socioeconomic status).

The geographic scope was varied for many of the data sources, or provided coverage of multiple geographical granularities. In the data sources pulled, 57 percent provided national coverage, 50 percent state coverage, and 32 percent county or city. Few or no data sources provided zip code (3%) or census block (0%) data.

Twenty-seven (38%) of the data systems contained individual-level data. However, some studies cannot share individual-level data due to Health Insurance Portability and Accountability Act restrictions and, thus, only offered aggregated-level data for sharing. In fact, 53 (74%) of the identified U.S. data systems offered aggregated data instead of individual-level data.

Figure 7 displays the outcome and exposure variables of interest in the U.S. data systems. Among data systems reporting the primary outcomes of interest in this report, weight was captured in 34 percent of the identified data systems, while height was available in 31 percent of them. Only 23 percent of the data systems offered a calculated BMI, while 42 percent of the data systems included information about dietary behaviors and 34 percent included information about physical activity. Almost half of the data systems contained information about at least one of the exposures with details about the studied policy, program, or built environment change, or contained geographical information. More than 31 percent of the data systems contained information about policies, 15 percent contained program-level information, and 48 percent contained geographical data [either as built environment data (24%) or other geographically encoded information (24%). Around 59 percent of the data systems included an objective approach (e.g., measurement by a healthcare provider; with or without other methods) to collect some of the outcome variables (not shown in the figure).

Figure 7 Coverage of obesity-related outcomes and exposures in U.S. data systems

BMI=body mass index

Note: Values in each group are not mutually exclusive and do not sum up to 100 percent, as a data system may cover multiple outcomes.

Figure 7 graphically illustrates obesity-related outcomes in U.S. Data systems defined by exposure (policy, program, built environment, or other geographical information), and primary outcomes (weight, height, BMI, diet, physical activity).