# Introduction

## Background

### Obesity and Its Public Health Consequences

The prevalence of overweight and obesity among adults and children has increased dramatically in the United States in recent years.^1^ Seventeen percent of U.S. children and adolescents are obese^2, 3^ and 69 percent of adults are overweight or obese.^4^ Obesity is now a worldwide epidemic, according to the World Health Organization, with an estimated 1.9 billion adults overweight or obese globally.^5, 6^ Obesity is associated with multiple adverse health consequences, including type-2 diabetes, cardiovascular disease, and many cancers,^7–10^ which have, in part, led to rising health care costs.^8, 11^ Economic implications of obesity also include higher absenteeism and reduced work productivity.^12^

The drivers of the obesity epidemic are complex, and involve intertwined, multilevel, and dynamic forces that influence health behaviors related to eating and physical activity, food systems, and access to physical activity-friendly environments.^13, 14^ Therefore, the search for effective solutions to prevent and control obesity needs to extend beyond the focus on the individual, to address the local neighborhood context, as well the social/cultural/political context unique to regions and countries.^6^ Since obesity is associated with racial and socioeconomic disparities,^15^ to successfully address obesity, we ultimately need programs and policies that can also reduce social and health inequities.

### Framework for Change: Public Health Policy and Neighborhood Approaches to Obesity Prevention and Control

In 2012, the Institute of Medicine (IOM) (see Appendix A for a list of acronyms) released a report entitled “Accelerating Progress in Obesity Prevention: Solving the Weight of the Nation.”^16^ The goal of the report was to evaluate strategies for their potential to prevent obesity. The Report identified several broad policy and programmatic goals, including making physical activity a routine part of life, creating a food/beverage environment that includes healthy options, creating messaging that can help to improve physical activity and nutrition, and using schools as an important focus. In addition, the report presented a “systems approach,” suggesting five critical areas—or environments for change: (1) environments for physical activity, (2) food and beverage environments, (3) message environments, (4) health care and work environments, and (5) school environments.

Aligned with the targets recommended by the IOM Report, non-governmental and governmental policies have been enacted and implemented. Examples include a sugar-sweetened beverage tax in Berkeley, California,^17^ menu or calorie-labeling regulations in New York City,^18–20^ and supporting new supermarkets in food deserts.^21^ In addition, many school systems have developed programs aimed at increasing children’s fruit and vegetable consumption, and increasing time spent outside during recess.^22, 23^ Rigorous published evaluations of these policies and programs, including those whose goal is to promote increased physical activity and active transportation, are enhancing the evidence base and increasing the ability of policymakers and funders to adapt, scale and disseminate those that are effective.^24^

Individual or group-based behavioral programs have been the cornerstone of effective weight loss interventions in adults.^25^ In their recommendations to increase physical activity and improve nutrition, the Centers for Disease Control and Prevention (CDC) included both the “systems” approach, as well as individually-focused, behaviorally-oriented programs to guide individuals in making changes in behavior.^26, 27^ Many behavioral interventions involve in-person or remotely delivered (phone/mobile phone/internet based) behavioral counseling to enhance individuals’ motivation to make and sustain decreased caloric intake and increased physical activity.^28^ Though often effective for short-term weight loss, the challenge with individually-focused interventions has been our ability to scale and sustain them in a community or healthcare setting. One example of a successfully scaled program is called CHAMPS (Community Healthy Activities Model Program for Seniors). After it was shown to be effective in a randomized controlled trial (RCT), CHAMPS was adapted for diverse communities and scaled for delivery in senior centers in San Francisco, California.^29^ The most recognizable behavioral weight loss trial, aimed at preventing type 2 diabetes in overweight adults, was the Diabetes Prevention Program (DPP).^30^ This intervention has been adapted as a community program and is being widely disseminated through the CDC’s National DPP program, with in-person and remotely-delivered classes in over 1,200 programs in the United States.^31^

## Challenges in Evaluating Programs, Policies, and Built Environment Changes Aimed at Preventing or Controlling Obesity

Challenges in evaluating obesity interventions stem in part from the complexity of the obesity problem, which tends to thwart interventions that focus on single and even multiple drivers of the problem, and in part from a lack of standards for designing and evaluating interventions.^6^ Evaluations need to take advantage of existing data sources; link policy, program or transportation data with clinical or health data, such as electronic health records (EHRs); and follow populations over time to assess impact. The National Institutes of Health, through multiple funding opportunity announcements and meetings, and the Patient Centered Outcomes Research Institute have invested in two types of studies to tackle the obesity epidemic: 1) traditional study designs involving a pragmatic clinical trial to integrate obesity care into primary care for underserved populations;^32^ 2) enhancement of the infrastructure of EHR data linked between health systems (called the Clinical Data Research Networks), to support observational studies about obesity.^33^ However, RCTs of obesity-prevention and control policies and programs may not always be feasible or appropriate. Economic, urban planning, systems-modeling and legislative policy evaluation approaches are being adapted to answer questions about the health impact, as well as the environmental and unintended positive and negative consequences of programs and policies.^34, 35^

### Natural Experiments To Address Obesity Prevention and Control

Novel approaches are needed to evaluate the effect of population health policies and programs, which are not always under the control of researchers using experimental designs. An important focus of this review is the opportunity to appraise and evaluate the approach known as a “natural experiment,” as well as other non-experimental designs, designed to study the effects of programs, policies, and changes to the built environment and social structures. Although natural experiments and other non-experimental designs are not new to public health, more publications are using the term “natural experiment,” and non-experimental designs are growing in popularity.^36^ For example, researchers used natural experiment approaches to examine the effect of regulation limiting the use of serotonin reuptake inhibitors in youth on suicide rates in the United Kingdom (UK),^37^ and of tobacco control policies on hospitalizations for acute myocardial infarction.^38–40^

To summarize the methodology and provide a standard definition, The UK’s Medical Research Council (MRC) recently released guidance to assist researchers in conducting and evaluating the rigor of natural experiment designs.^41, 42^ According to the MRC, the key features of a natural experiment are that “(1) the intervention is not undertaken for the purposes of research, and 2) the variation in exposure and outcomes is analyzed using methods that attempt to make causal inferences.”^41, 42^ Their natural experiment study definition was not limited to specific study designs. Applying the MRC definition to categorize existing studies is challenging, as few studies are explicitly labeled as natural experiments. In addition, the stage at which researchers and evaluators became involved with policies or programs may not always be clear, and even when it is, the degree of “control” the research team has may not be well described. Finally, although most studies using natural experiment approaches use non-experimental designs, it is also possible to embed a natural experiment within an RCT, such as the Moving to Opportunities study.^43^ In this study, the U.S. Department of Housing and Urban Development randomly assigned people to receive a rental subsidy in a low poverty neighborhood, with the goal of assessing social and economic outcomes. While not explicitly calling their work a natural experiment, health researchers took advantage of a randomized design to collect data about diabetes and obesity. They showed that the group with the voucher had a lower prevalence of severe obesity and diabetes.^43^

The goal of natural experiment designs is to obtain an approximate estimate of causality of a policy, program, or built-environment change on a public health outcome. The major challenge is in the selection of an “unexposed” comparison group. Selection bias is a common source of bias in natural experiment approaches. Many non-experimental study designs, such as use of propensity scores, interrupted time series, and regression discontinuity, are useful in identifying appropriate comparison groups.^44^ Most, but not all, natural experiment studies rely on existing data sources, and evaluating the strengths and limitations, and the types of measures these sources contain, is important to advancing future research.

The overarching goals of this review were to 1) improve understanding of the population-based data sources that have been used to evaluate programs, policies, and built environment changes designed to prevent or control obesity, and 2) identify methodological/analytic advances that would help strengthen future efforts to evaluate the programs, policies, and built environment changes related to obesity prevention and control. This review focuses on methods and does not evaluate the effectiveness of the programs and policies on the outcomes of interest. The review has a broad scope, including both natural experiment and experimental studies, to identify evaluations of programs, policies and built environment changes that aimed to prevent or control obesity in children and adults.

## Approach to Review and Identification of Key Questions

The Key Questions were identified to inform the Pathways to Prevention Workshop Methods for Evaluating Natural Experiments in Obesity. The results of this systematic review will provide background on the state of the evidence for this Workshop. To assist the reader, we also developed a glossary with definitions of key terms (Appendix B).

Our project sought to address the following Key Questions (KQs):

KQ1 What population-based data sources have been used in studies of how programs, policies, or built environment changes affect or are associated with obesity prevention and control outcomes?
KQ2 What methods have been used to link different population-based data sources?
KQ3 What obesity measures, dietary and physical behaviors, and other outcomes have been assessed in studies of how programs, policies, or built environment changes affect or are associated with obesity prevention and control?
KQ4 Which experimental and non-experimental methods have been used in studies of how programs, policies, or built environment changes affect or are associated with obesity prevention and control outcomes?
KQ5 What are the risks of bias in studies of how programs, policies, or built environment changes affect or are associated with obesity prevention and control outcomes?
KQ6 What methodological/analytic advances (e.g., data system features, approaches to linking data sources, or analytic methods) would help to strengthen efforts to estimate the effect of programs, policies, or built environment changes on obesity prevention and control?

## Scope of Review and PICOTS

We used the PICOTS typology ([underlined: P]opulations, [underlined: I]nterventions, [underlined: C]omparators, [underlined: O]utcomes, [underlined: T]iming, [underlined: S]etting) as a framework to define the scope of the review and inform the selection of studies of programs, policies or built environment changes targeting obesity. The PICOTS typology is a standard framework used in systematic reviews to be explicit and transparent about the inclusions/exclusions, search methods, study selection and data extraction, and is informative for discussions with stakeholders. Below we provide a rationale for the inclusion/exclusion criteria by PICOTS category,^45^ displayed in Table 1.

Table 1 PICOTS framework applied to Key Questions, with inclusions and exclusions described

[underlined: PICOTS] | Inclusions and Exclusions
[underlined: P]opulation(s) | Include:; - All ages, general population; and sub-populations of obese and overweight individuals; Exclude:; - Studies within specific clinical populations only, other than obese/overweight populations (e.g., severe mental illness, people with genetic predispositions for obesity).
[underlined: I]ntervention(s) | Include:; - U.S. and non-U.S. policies, programs, and built environment changes targeting a population.; Exclude:; - Programs or policies targeting individual-level intervention and change (not a system or population-level), e.g., Weight Watchers with individual or group-based behavioral counseling. [Note: if the program or policy includes multiple levels of intervention (e.g., population-level and individual-level) it would be included.]; - School-based studies that occur in a single school in the district.; - School-based studies that only involve a change to the curriculum without an environmental or systems change (e.g., nutrition education change in the health class).
[underlined: C]omparator(s) | Include:; - Studies with a clearly defined concurrent or non-concurrent comparison group either prior to the policy or a defined group without exposure to the policy or program; - Observational or cohort studies that use regression models to assess the association of a policy or program on an exposed versus an unexposed group.; Exclude:; - Studies without a comparison or unexposed group.
[underlined: O]utcome(s) | Include: [underlined: Outcomes of interest:]; - Body weight; - Body mass index; - Individual physical activity behavior assessed using a validated questionnaire that assesses both quantity and type of activity, or measures physical activity objectively (e.g., step counts).; - Individual dietary intake assessed using a validated questionnaire or 24-hour dietary recall, measuring one or more of the following:; - Total daily caloric intake,; - Specific dietary macronutrients related to obesity: vegetable, fruit, or fiber intake.; - Specific eating behaviors associated with obesity: sugar sweetened beverage intake, or fast food frequency.; [underlined: Co-outcomes:] Co-outcomes were described among included studies which had at least one “outcome of interest.” Co-outcomes were defined by the following categories: food-environment (e.g., perceived access to fruits and vegetables), physical activity environment (e.g., walkability, observed physical activity at a park or bike path), commuting behavior, and food purchasing behavior. Exclude:; - Studies without reference for validation or use of a validated instrument to measure diet or physical activity.; - Studies with observed behaviors as their only outcomes, such counts of people using a park or walking path, and studies using the SOPARC/SOPLAY tool for assessing physical activity at a park.
[underlined: T]iming | Programs and policies enacted or implemented in 2000 or later. The U.S. Surgeon General’s Call To Action To Prevent and Decrease Overweight and Obesity was published in 2001 and marked a turning point to raise public health awareness about obesity.^47^
[underlined: S]etting | Include:; - U.S. and non-U.S. settings at all levels (e.g., national, state, community/neighborhood).; Exclude:; - Studies in specific settings that would not be generalizable to a free-living population or community (e.g., prison, nursing home); - Studies in countries listed below the 2016 “human development index” (HDI) of “very high”.^48^

PICOTS: populations, interventions, comparators, outcomes, timing, setting;SOPARC/SOPLAY=system for observing play and recreation in communities/system for observing play and leisure activity in youth

### Populations

Studies were included if they targeted a community, school, or worksite population, with participants of any age. We included studies focused on one sub-population, i.e., studies conducted only within overweight or obese people. We excluded studies focused within other clinical sub-populations, such as people who had bariatric surgery or children with Prader-Willi syndrome, a genetic disorder.

### Interventions

We included studies of programs, policies or built environment changes targeting population-level behavior change, such as increased physical activity or healthier diet. We included programs, policies or built environment changes that may not have been originally developed for obesity control or prevention purposes, but were evaluated for this purpose. We excluded very broad policies that had very diffuse effects, such as the impact of cigarette taxes on obesity.^46^ We also excluded individually-focused behavioral interventions such as individual or group-based counseling programs.

### Comparators

We required studies to have a concurrent or non-concurrent comparison or unexposed group. We did not exclude studies based on other elements of study design, as the goal was to broadly describe the obesity natural experiment field and all study design approaches ranging from the strongest designs like RCTs to non-experimental approaches that defined an unexposed group. We did not want to exclude any study designs that had a comparison group, but rather wanted to describe the strengths and limitations of all approaches identified. In addition, evaluations of community- or school-based programs, policies and built environment changes employ a wide range of study designs from experimental to non-experimental. Community-wide obesity prevention studies, like The Massachusetts Childhood Obesity Research Demonstration Study, contain multiple programmatic and policy components, making it more difficult to discern at what point researchers become involved in the design and implementation.^49–51^ Therefore, we sought to describe the breadth of these approaches, the data sources and outcome measures they used, and the risks of bias associated with the designs, ultimately, to inform future research to advance obesity prevention and control.

### Outcomes and Measures

We focused on clinically relevant outcomes in adults and children, including weight and body mass index. We also included studies that reported on two main weight-related individual health behaviors, diet and physical activity. Defining the behavioral outcomes of dietary change and physical activity was challenging because many instruments rely on self-report, resulting in varying degrees of comprehensiveness, validity, and reliability.^52^ We categorized measures consistent with The National Collaborative on Childhood Obesity Research (NCCOR) Measures Registry^53^ for children’s measures, as well as the literature for adult measures.^54^ The NCCOR organizes the measures into Individual Diet, Food Environment, Individual Physical Activity, and Physical Activity Environment. We applied similar categories.^53^

The field of obesity control and prevention has advanced to having a large number of natural experiment studies that address weight, dietary intake and physical activity behaviors,^18, 43, 55–62^ so we excluded studies that only reported the food or physical activity environment or intermediate outcomes, such as measures of access to healthy food (e.g., stocking of shelves), fruit/vegetable purchases, distance to a park, or “walkability” of a neighborhood. We also excluded studies that only reported observed behaviors, such as the System for Observing Play and Recreation in Communities (SOPARC/SOPLAY),^63^ which assesses usage of park and recreation areas by observation rather than quantitative measurement of an individual’s change in type and quantity of physical activity. These studies record numbers of individuals engaged in certain activities, and do not measure duration of any of the activities. Finally, for all included studies, we reported on measures of the food-environment (e.g., perceived access to fruits and vegetables), physical activity environment (e.g., walkability, observed physical activity at a park or bike path), commuting behavior, or purchasing behavior, which we considered to be relevant “co-outcomes.”

### Timing

We focused on programs and policies enacted or implemented in 2000 or later. The U.S. Surgeon General’s Call To Action To Prevent and Decrease Overweight and Obesity was published in 2001 and marked a turning point to raise public health awareness about obesity. A previous systematic review also used 2000 as a starting date.^64^ We also performed preliminary searching that showed an exponential increase in studies meeting our search criteria were published each year after 2000, with an increase in natural experiment approaches after 2005.^36^

### Setting

We included studies evaluating policies, programs, and built environment changes within and outside the U.S. We excluded policies, programs, and built environment changes in countries below the 2016 “human development index” (HDI) of “very high,” to enhance consistency between programs and policies being evaluated across studies. The HDI is a composite statistic of life expectancy, education, and income per capita indicators. A country has a higher HDI when the life expectancy at birth is longer, the education period is longer, and the income per capita is higher. Fifty-one countries are listed in the “very high” HDI category.^48^

## Analytic Framework

Figure 1 depicts the KQs within the context of the PICOTS described in the previous section (Table 1). The figure illustrates the review’s focus on identifying data sources and linkages. It also shows that the review assesses the study designs and analytic methods that have been used to evaluate these programs and policies so that future research opportunities can be identified.

Figure 1 Analytic framework for obesity prevention and control

KQ=Key Question; SES=socioeconomic status

Figure 1 illustrates the review’s focus on identifying data sources and linkages. It also shows that the review assesses the study designs and analytic methods that have been used to evaluate the effects of these programs and policies so that future research opportunities can be identified.

## Organization of Report

This report is organized by chapter. Each chapter represents either a main section of the report (i.e., Introduction, General Methods), or a KQ. Due to the complexity of the report, we present general methods and results in one chapter, and KQ-specific methods and results in their own chapters.