# General Methods and Results

## Methods

### Search Methods

We conducted a systematic search of the published literature to identify studies focusing on programs and policies implemented for obesity prevention and control, including changes in the built environment. The results of this phase were used to address Key Questions (KQs) 1 through 5.

We searched PubMed, CINAHL, PsycINFO, and EconLit. A search strategy was developed for PubMed and used as a guide to develop search strategies for the other search engines. This search focused on identifying studies addressing obesity and behavioral changes impacting obesity. All databases were searched through August 21, 2017. Ten index articles identified by internal experts as applicable to this study were used during the search development. Terms used in the titles and abstracts, as well as relevant medical subject headings were identified in the index articles and used to develop the main search strategy. After the search strategy was developed, we tested it to ensure all index articles were captured.^18, 43, 55–62^ Detailed search strategies are described in Appendix C, Tables C1 and C2.

The search was supplemented with a hand search to identify references in other relevant systematic and narrative reviews. This hand search was conducted in two phases. The first phase involved searching the references of relevant systematic reviews captured in the main search strategy. Reference articles were selected through independent screening by two trained and experienced co-investigators with backgrounds in adult and child obesity prevention. These individuals identified potentially relevant articles based on the inclusion and exclusion criteria described below. Titles identified in this phase of the hand searching process were added to the main database of studies for full inclusion/exclusion review.

The second phase of the hand search involved a search for systematic reviews in PubMed focusing on change in diet and physical activity outcomes without requiring any mention of obesity (detailed search strategy is described in Appendix C, Table C3). This search was developed using an additional set of index articles suggested by experts. Those index articles had not been identified by the original search strategy (which focused on finding articles that referred to obesity, overweight, or body mass index (BMI)).^65–71^ If we had expanded the original search by not requiring any mention of obesity, overweight or BMI, we would have had an unmanageable number of citations to review. We decided that the best way to identify eligible studies that focused on diet and physical activity outcomes was to search for relevant systematic reviews from 2013 through July 2017. The systematic reviews were evaluated for applicability to this study by two individuals who were involved in the main search and screening protocol. If a systematic review was considered applicable after the abstract and full text was reviewed, references for the included articles in each review were identified, and added to the main pool of articles for inclusion or exclusion.

We limited the search to studies published between 2000 and August 21, 2017. This time frame was selected to encompass the U.S. Surgeon General’s report, “The Surgeon General’s Call To Action To Prevent and Decrease Overweight and Obesity,” released in 2001 and calling attention to the major public health problem of obesity.^47^ The publication of this report marked a shift toward directing public health funding and policies toward the prevention and control of obesity and sparked new research in this area. We gathered information on the number of articles captured using the original search strategy, and we identified the number of articles published per year. In 2000, the search captured 286 titles. This number steadily increased to 2698 in 2016.

### Inclusion and Exclusion Criteria

The inclusion and exclusion criteria for the systematic review were derived from the PICOTS (populations, interventions, comparators, outcomes, timing, setting) framework (Table 1). We searched for all studies of programs, policies, or changes in the built environment targeting obesity prevention and control, change in physical activity behaviors, or change in diet behaviors, in people of any age to identify potential data sources.

Abstracts and full text articles were screened by two types of people (screeners). We included screeners who are considered “junior,” meaning they are not experts in the field, are experienced research assistants working in systematic reviews, and are trained by the program manager to understand the inclusion and exclusion parameters of this project. “Senior” screeners are project leaders (principal investigators, investigators, and senior-level managers) who have either a clinical background on the topic of obesity prevention, or multiple years of experience developing and conducting systematic review screening processes. All abstracts, and all potentially relevant full text articles were reviewed by one junior screener and one senior screener. Agreement on inclusion or exclusion was required. Disagreements between screeners were discussed and, if they could not be resolved, were adjudicated by a third-party screener.

Abstracts were excluded for the following reasons:

- No original data
- Study of fewer than 100 participants total
- Does not address a change in the built environment or is not a population-based program or policy
- No comparison group, unexposed group, or pre-post comparison
- Studies in a setting not generalizable to a free-living population or community
- Study only targets a specific clinical sub-population (e.g., children with Prader Willi syndrome or people with severe mental illness) other than obese and overweight populations. Note if a sub-population was included within the broader population, study was not excluded.
- Not relevant to the KQs
- No abstract
- No human data reported
- Not in English
- Protocol of a relevant study not reporting preliminary data

Full-text articles were excluded for the reasons above as well as the following:

- Outcomes were outside of the parameters of this review (see Table 1 for outcomes list)
- Study measured only a specific micro/macronutrient or dietary health behavior
- Meeting abstract
- Policy or program was not focused on obesity or nutrition-related structural or environmental changes
- Programs and policies enacted or implemented prior to 2000
- Study conducted in a single school.
- A school-based policy or program that only included a curriculum change without evidence of a structural or environmental component
- Study took place in a country that does not have a “very high Human Development Index (HDI),” based on the United Nations Development Programme, Human Development Reports.^72^ The HDI is a composite statistic of life expectancy, education, and income per capita indicators. A country has a higher HDI when the life expectancy at birth is longer, the education period is longer, and the income per capita is higher.

We included studies that reported on at least one of the following outcomes of interest: obesity measures (either body weight or BMI in adults or BMI z-score or BMI percentile in children) or obesity-related individual health behaviors (dietary and physical activity) (Table 1 lists the outcomes of interest in detail).

### Data Abstraction and Data Management

We used Distiller SR software (Evidence Partners, Ottawa, Canada) for data collection and reporting during the review process. Distiller SR is a Web-based data management program for systematic reviews and literature reviews that manages all levels of the review process. Data from applicable studies was abstracted in Distiller SR using predefined data abstraction forms (Appendix D) and will be uploaded to the Systematic Review Data Repository^TM^ (SRDR), a Web-based data repository, at the completion of this project. This source serves as both an archive and a data abstraction tool. Data will be exported to SRDR in a project-specific database to serve as archived or backup copies and to create detailed evidence and summary tables.

#### Data Abstraction Overview and Process

For each included study, two trained research assistants abstracted data about the study’s characteristics (e.g., year of publication, country), study design, participants and populations, the policy and/or program evaluated, year of enactment, type of legislation/policy, location of policy (e.g., state, country, locality), original goal of policy/program (diet, physical activity, both, other), data sources and linkages, and analytic methods. See below for additional data abstraction elements by KQ. We also assessed how each of the outcomes was measured and whether a validated reference for instruments was provided.

After the data were abstracted, an independent data abstraction expert reviewed a random sample for quality assurance. Data abstraction experts were project leaders (principal investigators, investigators, and senior-level managers) who have either a clinical background on the topic of obesity prevention, or multiple years of experience developing and conducting systematic review screening processes. Inconsistencies in data abstraction were resolved by a consensus approach involving the research assistants and the expert reviewer. If consensus was not attainable for a specific case, it was discussed among the project leaders (principal investigators, investigators, and senior-level managers) and resolved by a majority vote. The same process was used for all data abstraction activities throughout this project.

### Grading Strength of Evidence

We assessed the overall risk of bias in the studies as described above. We did not evaluate the overall strength of evidence for a particular comparison or outcome as we are not assessing the comparative effectiveness of policies or programs (interventions) in this review. Thus, we did not assess other domains of strength of evidence, such as consistency between studies, precision of estimated effects, or whether studies provided direct estimates of effects on the most important outcomes of interest.

### Assessing Applicability

We assessed applicability in terms of the PICOTS framework, as well as in terms of each of the KQs.

### General Data Abstraction

#### Study and Participant Characteristics

Study and participant characteristics were abstracted for all included studies. Table 2 lists the study and participant characteristic categories and details abstracted. See Appendix D for the data abstraction form.

Table 2 Study and participant characteristics abstracted

Study Characteristic | Details
Study Design (see below) | Natural experiment study Experimental study Other study design
Study Dates | Start date End date Not reported
Community Type | Urban Suburban Rural Not described
Study Setting | Early childhood education or daycare (e.g., pre-school, Head Start) School: elementary (K-5); middle (6–8); high (9–12); other University After school or summer school Senior center Community center (e.g., job training, youth) Community or neighborhood (e.g., parks, farmers markets) Employer or worksite Transportation (e.g., train, bus, car, walking) Other Settings
Inclusion and Exclusion Criteria | - Define whether the criteria applied to individuals, site, or not specified; - Specific criteria:; Sex; Age; Race/ethnicity; Other
Participant Characteristics
Comparison Group | Identification of all comparison groups in the study
Population Size | Baseline N, follow-up period, and N at last follow-up for each comparison group.
Baseline Data | Sex Age category or grade category Pre-intervention weight or BMI (adult): weight; BMI; BMI category Pre-intervention BMI (child): BMI z-score; BMI percentile

BMI=body mass index; N=number

Because of the focus of this review on methods for natural experiment studies on obesity, we classified studies as either natural experiment studies, experimental studies, or other study designs. We used the definition of a natural experiment as proposed by the MRC (see Appendix B).^41^ Studies in which the researchers had control of the intervention and assigned participants or communities to intervention and control conditions were classified as experimental studies, which included both RCTs and controlled clinical trials. When the intervention was assigned to intervention and control groups by factors outside of the control of investigators, we classified the study as a “natural experiment study.” Studies for which there was not sufficient information on the assignment mechanism to determine whether a natural experiment or experiment approach was used were labeled as “other study design.” Study designs were further classified in the description of Methods for KQ 4.

#### Interventions: Policy, Program, or Built Environment Change

Intervention details were abstracted for all included studies. A number of studies included multiple interventions. Each intervention was abstracted. Table 3 lists the information abstracted about the interventions. The categories for the intervention targets were based on the 2012 Institute of Medicine (IOM) Report.^16^ See Appendix D for the data abstraction form.

Table 3 Intervention details abstracted

Study Characteristic | Details
Goal of the program, policy, or built environment change | Physical activity environment (e.g., increasing opportunities for walking in low resource areas) Food and beverage environment (e.g., food assistance programs, farmers market) Messaging environment, about nutrition or physical activity (e.g., food labeling, food marketing) Healthcare environment (health insurance, health system, or healthcare providers) Work environment (e.g., active living; healthy living at work) Physical and built environment (e.g., transit, park, other outdoor spaces, farmers’ markets, new supermarkets) Other
Was a policy evaluated? | If yes:; - Name of the policy; - Governmental; - Federal/National (specify country); - If United States, provide bill name and number; - Date of passage, date of enactment; - Is the policy still in effect?; - State/province/region (specify); - If U.S. State, provide bill name and number; - Date of passage, date of enactment; - Is the policy still in effect?; - Local/community (specify); - Date of passage, date of enactment; - Is the policy still in effect?; - Non-governmental; - Organization implementing the policy; - Policy start and end year
Was a program evaluated? | If yes:; - Name of the program; - Governmental; - Federal/National (specify country); - Program start and end date; - State/province/region (specify); - Program start and end date; - Local/community (specify); - Program start and end date; - Non-governmental; - Organization implementing the program; - program start and end year
Was a built environment or other change evaluated? | If yes:; - Name and nature of the built environment or other change; - Federal/National (specify country); - Built environment start and end date; - State/province/region (specify); - Built environment start and end date; - Local/community (specify); - Built environment start and end date

## Results

### Results of Literature Search

The literature search identified 26,316 unique citations, of which 294 studies (reported in 312 articles) were eligible for inclusion (Figure 2). See Appendix G for a list of included studies

Figure 2 Results of literature search

Figure 2 depicts the flow of the literature review. A total of 26,316 unique articles were identifed by searching PubMed, CINAHL, PsycINFO, EconLit, through a hand search, and a supplemental search. Title and abstract screening excluded 25,093 articles as ineligible, leaving 1223 for full text screening. After full text screening 911 articles were excluded leaving 294 strudies reported on in 312 articles.

### General Study Details

We included studies that occurred in both the United States and other countries. The majority of studies were within the United States (n=188). One hundred and six were included from outside the United States, with Canada, the UK, and Italy most common after to the United States.

We classified all studies by study design. The methods section describes the classification process (see Appendix B, Glossary). About half of the studies were natural experiment studies (n=156, 53%), followed by experimental studies (randomized controlled trials or non-randomized controlled trials) (n=118, 40%), and other study designs that did not fall into either of the other categories (n=20, 7%). Results that follow from each of the KQs are also described within these study design classifications, followed by a description by population and setting.

We included detailed information on each study, the participant characteristics, and information on policy, program and built environment interventions in Appendix H (Evidence Tables H1 and H2).

### Programs, Policies, and Built or Environmental Changes Identified in Included Studies

We identified the original programmatic or policy goals of the program, policy or built environment change in reported in each study based on critical areas (or environments) for change from the IOM Report (2012).^16^ These included: environments for physical activity, food and beverage environments, message environments (posted flyers or information campaigns), health care environments and work environments, transportation environments, parks and recreation environments (See Methods for Data Abstraction and Appendix B for Glossary); studies often were classified as having more than one goal. In addition, studies were described by target setting, such as work, school or community. Table 4 provides information on the number of studies classified by study method, program, policy, or built environmental goals, and the target settings.

Table 4 Summary of study methods; programs, policies, and built environment goals; and targets of intervention (N=294)

Study design, n Studies | Programmatic, Policy, or Built Environment Goal, n Studies^*^ | Target Setting of the Program, Policy or Built Environment Change, n Studies
Natural experiment studies, n=156 | Physical activity environment, 43 | School, 34 Community or neighborhood, 8 Transportation, 1
Natural experiment studies, n=156 | Food and beverage environment, 78 | School, 50 Food assistance program^†^, 9 Community or neighborhood, 19
Natural experiment studies, n=156 | Transportation, 17 | Community or neighborhood, 17
Natural experiment studies, n=156 | Parks and recreation, 8 | Community or neighborhood, 8
Natural experiment studies, n=156 | Messaging environment,^‡^ 9 | School, 4 Community or neighborhood, 5
Natural experiment studies, n=156 | Physical and built environment, 33 | School, 4 Community or neighborhood, 28 Employer or worksite, 1
Natural experiment studies, n=156 | Policy, 11 | School, 8 Community or neighborhood, 3
Experimental studies, n=118 | Physical activity environment, 57 | School, 50 Community or neighborhood, 4 Employer or worksite, 3
Experimental studies, n=118 | Food and beverage environment, 65 | School, 48 University, 1 Community or neighborhood, 10 Employer or worksite, 7
Experimental studies, n=118 | Transportation, 1 | Employer of worksite 1
Experimental studies, n=118 | Parks and recreation, 1 | Community or neighborhood, 1
Experimental studies, n=118 | Messaging environment, ^‡^ 16 | School, 4 University, 2 Community or neighborhood, 6 Employer or worksite, 4
Experimental studies, n=118 | Healthcare, 1 | Other (National Health Service intervention), 1
Experimental studies, n=118 | Work, 1 | Community or neighborhood, 1
Experimental studies, n=118 | Physical and built environment, 16 | School, 5 Community or neighborhood, 10 Employer or worksite, 1
Experimental studies, n=118 | Other Policy, 2 | School, 2
Other study designs, n=20 | Physical activity environment, 11 | School, 8 Food assistance program^†^, 1 Community or neighborhood, 2
Other study designs, n=20 | Food and beverage environment, 6 | School, 1 Food assistance program^†^, 1 Community or neighborhood, 1 Employer or worksite, 3
Other study designs, n=20 | Messaging environment, ^‡^ 4 | School, 2 Community or neighborhood, 2
Other study designs, n=20 | Transportation, 1 | School, 1
Other study designs, n=20 | Physical and built, 2 | School, 1 Community or neighborhood, 1

N=total population; n=number of studies

* Some studies include multiple program, policy, or built environmental goals; some studies include multiple intervention targets

† Examples of food assistance programs include SNAP (Supplemental Nutrition Assistance Program), a federal level program; Health Bucks, as local-level farmer’s market incentive program

‡ Consistent with the 2012 IOM Report that described “Message Environments”, policies and programs were classified as having specific messages or information about nutrition and/or physical activity (e.g., posted flyers or informational campaigns), which included social marketing strategies.

Eighty-six studies out of 294 reported having multiple programmatic, policy or environmental goals. Most studies, regardless of study design, targeted schools and addressed changes in the environments for physical activity or the food and beverage environment. Nearly all of the studies addressing changes in the transportation or parks and recreation environments (n=27) followed a natural experiment method and targeted communities or neighborhoods (Table 4).

The majority (n=152 studies) of the 188 U.S. studies across all study designs evaluated governmental programs or policies at the local, state/regional, or federal levels. Of these, we identified 139 unique policy or program evaluations (Appendix I, Table I1). Eighty-five of these studies evaluate programs, and fifty-five are evaluations of policies. For example, polices included those addressing food policy (sugar-sweetened beverage bans;^73^ competitive food laws^74^; calorie labeling laws;^19, 20^ Women, Infants, and Children and Supplemental Nutrition Assistance Program,^61, 75, 76^ physical activity policy joint use policies;^77^ state policies on physical education;^78, 79^ physical activity in daycare centers^80^). Additionally, we identified 36 non-governmental programs (Appendix I, Table I2).

Forty-eight (31%) of the 156 natural experiment studies took place outside of the United States, and 62 percent focused primarily on children. Sixty-three percent of the natural experiment studies taking place in the United States (n=108) focused on children. Fifty (42 %) of the 118 experimental studies took place outside of the United States, and 73 percent focused primarily on children. Sixty-nine percent of the experimental studies taking place in the United States (n=68) focused on children. Seven of the 20 studies with other study designs took place outside of the United States, and 4 of them focused primarily on children, while the rest were in the United States, of which 7 focused on children.

The natural experiment studies most commonly evaluated national, state, and local policies such as the UK’s provision of free local bus passes to retirees ^81^ or the 2008 legislation requiring chain restaurants in New York City to provide calorie information to be posted on menus ^20^. Researchers also commonly capitalized on changes to local built environments such as the addition of new supermarkets in food deserts^21, 55, 82^ or new transportation systems.^56, 66, 83^ We included evaluations of programs that were not originally intended for research, such the Centers for Disease Control and Prevention’s HealthMPowers program ^84^ to improve physical activity and nutrition in the school setting and Jamie Oliver’s cooking skills program.^85^