# Key Messages

- Relevant programs, policies, or built environment changes were evaluated in 156 natural experiments, 118 experimental studies, and 20 other studies.
- Criteria for a data system (source exists, is available for research, is sharable, and has outcomes of interest) were met by 106 data sources.
- Thirty-seven percent of U.S. data systems were linked to secondary data.
- Outcome measures included dietary behavior (148 studies), physical activity (152 studies), childhood weight (112 studies), and adult weight (32 studies).
- Natural experiments most commonly used regression models comparing exposed and unexposed groups at one time.
- Natural experiments generally had moderate risk of selection bias and high risk of bias for losses to follow-up.
- Research could be advanced by more use of data dictionaries, reporting standards on data linkage, long-term obesity-related outcomes, and study designs with multiple pre- and post-exposure time points.