# Purpose of Review

To characterize studies of programs and policies in obesity prevention and control in terms of data sources, data linkages, measures reported, study designs, and analytic approaches, and to identify needed methodological advances.