# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- David Allison, Ph.D.^*^
  Dean and Provost Professor
  Indiana University School of Public Health
  Bloomington, IN
- Cheryl Anderson, Ph.D., M.P.H.^*^
  Associate Professor
  Department of Family Medicine and Public Health
  University of California, San Diego
  La Jolla, CA
- Donna Coffman, Ph.D.^*^
  Dept. of Epidemiology and Biostatistics
  Temple University
  Philadelphia, PA
- Trina Histon, Ph.D.
  Senior Principal Consultant
  Kaiser Permanente
  Oakland, CA
- Lisa Sanbonmatsu, Ph.D.^*^
  National Bureau of Economic Research
  Cambridge, MA
- Brandon Simms
  Greater Gethsemane Missionary Baptist Church
  Baltimore, MD
- Xuemei Zhu, Ph.D.^*^
  Associate Professor
  University of Texas College of Architecture
  Texas A&M University
  College Station, TX

* Provided input on Draft Report.