# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Jessica Gayleard, Ritu Sharma, Catalina Suarez, and Lisa Wilson.