# Discussion

We conducted a systematic review of studies that evaluate how policies, programs, and built environment changes affect obesity prevention and control outcomes. For Key Question (KQ) 1 and KQ 2, we focused on summarizing and evaluating the data sources and data linkages used in those studies. For KQ 3, we summarized how studies assessed childhood and adult obesity outcomes, dietary and physical activity behaviors, and other co-outcomes (e.g., commuting behavior). For KQ 4 and KQ 5, we evaluated the risks of bias in the experimental and non-experimental studies. For KQ 6, we identified specific methodological/analytic advances that could strengthen efforts to estimate the effectiveness of programs, policies, and built environment changes intended to improve obesity prevention and control.

We identified 294 studies (including 156 natural experiment studies), a majority of which were conducted in the United States. We included a wide range of policies, programs and built environment changes, including 152 studies that evaluated governmental programs or policies at the local, state/regional, or federal levels with 139 unique policy or program evaluations.

For KQs 1 and 2, we reported on 93 studies using a primary or secondary data source that were sharable with other researchers, with a total of 116 unique data sources. Among these, 106 data sources met criteria for being a data system. Data systems represent organized, accessible data sources that go behind just collecting and managing data, but also have some degree of an information technology infrastructure to maintain and operate the system. Of the 106 data systems, 96 were used in natural experiments. One third of the 71 US data systems were linked with a data source other than a primary data source, most commonly using a geographic allocation (e.g., by county or zip code) or at the individual-level.

For KQ 3, we found 112 studies with childhood BMI/weight outcomes (50 were natural experiment studies), 32 studies with adult weight/BMI outcomes (17 were natural experiment studies), 148 studies with dietary behaviors (77 were natural experiment studies) and 152 studies on physical activity (71 were natural experiment studies). Thirty-seven of the studies also reported on commuting behaviors, food environment, physical environment, or food purchasing behaviors. Weight was most commonly directly measured by trained staff. Questionnaires for assessing dietary behaviors included the School Physical Activity and Nutrition and Youth Risk Behavior Survey (YRBS) Questionnaires in children, and the Behavioral Risk Factor Surveillance System (BRFSS) in adults. The most common methods for assessing physical activity were questionnaires and electronic monitoring, e.g., pedometers, for all types of study designs.

For KQs 4 and 5, natural experiment studies most commonly used regression models to compare exposed and unexposed groups at a single time point (35%). The next most common analytic approach was comparing exposed and unexposed groups using difference-in-difference methods (29%), followed by pre/post designs that compared one group before and after an exposure (31%). Fewer studies used instrumental variable, regression discontinuity or interrupted time series approaches with more than 2 time points pre- and post-intervention. Most natural experiment studies were rated as having a “weak” global rating (i.e., high risk of bias) due to handling of withdrawals and dropouts, weak study design and weak handling of confounding.

## Findings in Relationship to What Is Already Known

Our systematic review is the first to focus on describing and appraising the methods (data sources, study design, and analytic approaches and risks of bias), used in natural experiment studies of policies, programs, and built environment changes to prevent and control obesity. Our review was broad and comprehensive, and included both U.S. and non-U.S. studies, all types of policy, programmatic and built environment interventions and all study designs. Although our review focused on evaluating the methods, other recent systematic reviews identified many of the same articles but focused on assessing the effectiveness of certain types of policies or programs, such as on food environment policies,^24, 109–111^ (e.g., the review by Sisnowski et al. included 36 articles), or built environment changes (e.g., reviews by Ferdinand et al included 169 articles ^109^ and Mayne et al included 37 articles^36^), as well as specific settings such as school-based programs or policies^112^ (included 32 articles). Another 2013 systematic review included 147 studies focused on the effectiveness of childhood obesity prevention.^113^ Finally, Gudzune and colleagues’ systematic review focused on the prevention of weight gain in the worksite or college settings.^114^

Our systematic review has several significant and original contributions to advance the field of obesity prevention and control, particularly for informing the future design and reporting of natural experiment studies related to obesity prevention and control. Although a few prior studies have described the current state of data sources and data linkages in public health research (e.g., a review of data systems for the field of suicide prevention),^86^ no studies have created this list in the field of obesity, which will be useful for future obesity research. Additionally, for obesity measures, a database of measures exists for childhood obesity, called the National Collaborative on Childhood Obesity Research (NCCOR) Measures Registry,^53^ but no database exists for adult obesity research. The NCCOR serves to catalog the data sources, but does not assess which measures are used in research or other evaluations, which is a major contribution of our examination of KQ 3. Finally, for KQs 4 and 5, we described study designs and analytic approaches currently being used in natural experiment studies, and determined the extent to which studies were limited by specific types of bias. While there is growing interest in using natural experiments to evaluate obesity policies and programs, a major contribution of our review was to highlight areas for improvement in the approaches, and the need for stronger guidance and standards for evaluators to report their designs and findings to enhance trust in their results.

## Applicability

The applicability of our review and the identified studies depended on the diversity of study populations, obesity policies and programs, and outcomes assessed. We summarized applicability in terms of the populations, interventions, comparators, outcomes, timing, setting framework, as well as in terms of each of the KQs.

The populations of the studies included both obese and non-obese children and adults, and these populations were generally applicable to other populations and communities. However, of the 261 studies, the majority were of children, with fewer evaluations of policies and programs in adult populations or community (non-school) settings. Many studies did not report the races and ethnicities of their populations being studies. Of those that reported race and ethnicity, few studies included Native Americans, or targeted a high proportion of Hispanics.

We included interventions that were governmental and non-governmental population-based programs. We identified a wide range of obesity-related policies and programs, including state- (e.g., Arkansas Act 1220 focused on school nutrition and physical activity)^115^ and federal-level legislation (e.g., Food Stamp Program).^75, 116–120^ These evaluations of policies and programs are applicable and specific to the setting where the policy or program was enacted and implemented.

To enhance applicability of the review, we included studies that reported health outcomes and behaviors important to policymakers, program evaluators, researchers and clinicians, namely weight, dietary behaviors and physical activity. Many studies reported on childhood weight outcomes with fewer studies reporting on adult weight or body mass index. Even more studies reported dietary or physical activity measures. These outcomes are applicable to the population of interest, and are important for assessing the impact of obesity related policies and programs, particularly given the growing epidemic of obesity in both adults and children. Although weight and behavior change may be long-term outcomes, some evaluations of programs and policies have begun to demonstrate significant impact on these outcomes.^19, 56^

The studies’ settings were both in the United States and other countries, and set in the workplace, school and diverse communities. We included a total of 106 studies from outside the United States. Few studies reported their setting as within a rural community.

Regarding the applicability of KQ1 results, we showed that the majority of the U.S. data systems were statewide or nationally representative. Data systems with a state-level focus were mainly collected in California, New York, Massachusetts, Minnesota, Pennsylvania, Texas and Alaska. Most of the U.S. data systems had a focus on schools or communities.

For KQ4 and KQ5, we described methods and risks of bias in natural experiment studies, as well as experimental designs, and highlighted the strengths, as well as risks of bias associated with each of them. Although randomized controlled trials (RCTs) are considered the gold standard to reduce risks of bias, RCTs are challenging to implement due to high cost and often randomization of participants or communities to policies or programs is not feasible. To improve the applicability and validity of their evaluations, researchers could consider innovative trial designs that would allow randomization, such as stepped wedge or waitlist control designs. However, few studies used these approaches. The questions in obesity policy research are well suited for natural experiment study designs to increase the internal and external validity of their studies when assessing causal effects.

## Limitations of the Systematic Review Process

We noted several limitations to our systematic review process. First, we developed several exclusions, most significantly excluding: studies without a clear comparison or unexposed group or time period; studies without a defined population-based program, policy, or built environment change; and studies without our main outcomes of weight or obesity-related health behavior. Examples of studies that we excluded are those that assessed the associations between perceived or measured home, school, or physical environment and various weight-related outcomes (e.g., Wong et al. 2016^121^) but without a described program, policy, or change in the environment. We sometimes excluded studies that evaluated policies because they did not include one of our main outcomes, such as the study by Chen and colleagues evaluating the effect of menu labeling on change in caloric information awareness,^58^ but without a measure of change in dietary intake. We also excluded park and transportation studies that reported observed number of users of the park or form of transportation, instead of the individual–level change in physical activity. For example, a study by Fitzhugh and colleagues assessed the effect of an urban greenway/trail on directly observed physical activity in the general neighborhood and school, but did not have measures of individual behavior change, which we required in this review.^122^

Second, regarding our evaluation of data sources and linkages, we limited our full assessment of data specifications to studies conducted in the United States to enable consistent access and identification of codebooks in English. However, even among these data sources, our ability to fully assess data quality was limited by the low availability of online codebooks and data dictionaries.

Third, although the focus of the review was to improve our understanding of obesity-related natural experiments, the definition of what methods and designs meet a definition of a “natural experiment” continues to evolve. As described in the Methods, we classified “natural experiments” according to the MRC^41^ definition as those where “the intervention/control was assigned to participants/communities/schools by factors outside the control of the investigators.” In applying this definition, we identified some studies where it was not clear. For example, one study evaluated the Healthy Hawaii initiative and provided trends in percent of population eating fruits and vegetables by year, but it was neither a natural experiment study nor an experimental design.^123^ We presented the findings of this review by “natural experiment”, experimental designs, and other non-experimental designs, in order to compare within and across study design approaches, and also to avoid being constrained by an evolving, and often subjective, natural experiment definition.

Fourth, we relied on a previously developed risk of bias assessment tool. No well-established risk of bias assessment tool exists specifically for natural experiment studies. To enable comparisons across all study designs (both experimental and non-experimental) included in the review, our goal was to use a single tool. A general tool such as the Effective Public Health Practice Project (EPHPP) is useful for gathering information on risk of bias due to a number of bias concerns, including measurement error and loss to follow-up and withdrawals. However, tools like EPHPP have been criticized for being overly rigorous and failing to take into account feasibility, implementation and future scalability, which are important issues for natural experiment studies. In addition, risk of bias tools, including the EPHPP, are designed to evaluate internal validity and not external validity, while the strength of a natural experiment study is to enhance generalizability and external validity, which these tools may not address. In its guidance, the UK’s Medical Research Council (MRC) ^41^ suggested using a different risk of bias assessment tool for natural experiment studies, the Newcastle-Ottawa Scale,^98^, which was developed for cohort studies. We additionally applied the Newcastle-Ottawa Scale for cohort studies^98^ to a randomly selected subset of natural experiment studies. The Newcastle-Ottawa Scale has fewer domains and no global score, making it challenging to compare between the two tools. Overall, we showed that the natural experiment studies were similarly rated as “weak” in terms of risk of bias, across both the EPHPP tool and the Newcastle-Ottawa Scale. The EPHPP and our specific study design approach had other limitations, including our inability to detect the degree of risk from type 2 error among smaller RCTs or cluster RCTs with few clusters. An additional challenge was that any non-experimental study involves some untestable assumptions, and thus we could not directly assess bias but, rather, could only assess the likely validity of the assumptions underlying each approach. In addition, few of the studies did formal assessments of the robustness of results to violations of those assumptions.

## Limitations of the Current Evidence

We identified several limitations of the current evidence on methods for obesity-related natural experiments and other evaluations of obesity prevention and control policies and programs. First, the current evidence base not does yet take advantage of the plethora of available data sources on obesity. Natural experiment studies used many national health surveys such as National Health and Nutrition Examination Survey ^124^ and BRFSS.^125^ The Patient Centered Outcomes Research Institute (PCORI) has established PCORNet with 13 Clinical Data Research and 20 Patient Powered Research networks to link patient data longitudinally across patient organizations as well as large health systems in the United States.^126^ Although the infrastructure is still under development and testing, PCORNet provides an example of how health care data and outcomes could be used to evaluate obesity prevention policies and programs, especially through linkages with other public health data sources. In addition, the Natural Experiments for Translation in Diabetes collaborations provide examples of how health systems are using natural experiment approaches to evaluate diabetes management and prevention approaches, including telephonic health coaching programs, insurance policies involving high deductibles, early diabetes detection in primary care, and national scaling of the Diabetes Prevention Program.^127^ Further, to improve the ability of obesity researchers to use and link data sources with spatial attributes, these data should contain consistent spatial units of analysis that can be easily linked together. For example, census data and traffic data may come in with different spatial units, which makes it difficult to link these data together.

As with other obesity prevention and control studies, natural experiments have many of the same challenges in terms of obtaining valid and reliable measures of dietary intake, physical activity and weight status. All obesity prevention studies should aim to find practical ways to obtain high quality, reliable measures and ensure that the assessment of these variables in other data systems be of the highest possible quality. In our review, we identified several different measures for obesity outcomes. For example, for childhood obesity, we described the use of standard measures, such as change in body mass index (BMI) z-score or BMI percentile; however, several studies used other non-standard measures in children, such as absolute BMI change or weight change in children. We identified a need for population-based studies to use objective measures of diet (e.g., 24 hour recalls) and physical activity (e.g., accelerometers), and to expand measures of body composition beyond body mass index. Additionally, we identified very few studies that reported on co-outcomes or unintended consequences associated with policies or programs.

This review provided a unique opportunity to describe the current evidence in terms of study design and analytic approaches, including natural experiment studies and experimental approaches to evaluate policy and program interventions for obesity prevention and control. Although RCTs are the gold standard for clinical efficacy research, they are often impractical and/or costly when testing the effectiveness of policies or programs that are new or have been adapted from other settings. The MRC’s definition of natural experiments involves studies with “unplanned variation in the exposure of interest.”^41^ Because experimental studies also have limitations and biases, in our review we chose to include both experimental designs where the exposure of interest was controlled, as well as non-experimental studies with “unplanned variation” in the exposure.

Among the natural experiment studies, we expected to find common non-experimental designs, such as instrumental variables, regression discontinuity, propensity score, and interrupted time series methods. However, we showed that few studies used these study designs that could improve causal inferences. It is possible that use of instrumental variables is limited by difficulties in selecting appropriate instrumental variables with the data typically available to researchers in this field. By far the most common design was cross-sectional regression models. In addition, many studies failed to present a table of covariate balance across groups to enable assessment of risk of bias due to confounding. Among the natural experiment study designs, an evaluation of Arkansas’ Act 1220 was rated as having lower risk of bias.^115^ They used a comparison group design using a difference in difference approach to assess the effect of Arkansas Act 1220’s mandate on BMI screening in public schools on BMI z-score, using the Centers for Disease Control and Prevention (CDC)’s YRBS.^115^ This study received a higher EPHPP rating because it used both valid and reliable data collection tools, was rated as being generalizable, and neither participants nor outcome assessors knew the exposure status of the participants. For pre/post studies (i.e., where an exposed group was compared to itself in a prior time period), the average number of time points pre- and post-intervention was 1 and 1.4, respectively. For difference-in-difference studies, which use changes in time and across groups, there were an average of 1 and 1.1 time points pre- and post-intervention. The MRC recommends multiple pre- and post- measures to improve the design of natural experiment studies, especially when a control group is not available as in the pre/post designs.^41^ Among the studies included in this review, all pre/post studies measured variables at a single time point pre-intervention, and 86 percent had a single measure post-intervention. Depending on the research question, the type of natural experiment being evaluated, and the stability of the outcome of interest, adding multiple time points should improve study validity, but could have cost/time implications for researchers and funders.

A standard definition of selection bias is “bias in the estimated association or effect of an exposure on an outcome that arises from the procedures used to select individuals into the study or the analysis”.^128^ When the selection involves conditioning on a factor that is affected by the exposure or a cause of the exposure, and also affected by the outcome or a cause of the outcome, selection bias can arise even in the absence of a causal effect of exposure on outcome, i.e., under the causal null hypothesis. Because such uses of “selection bias” do not imply lack of internal validity, it is more appropriate to use the expressions “lack of generalizability” or “low external validity.” To include concerns about external validity, which is particularly relevant to natural experiment studies, we applied the EPHPP’s definition of selection bias to natural experiment studies, assessing to what extent the individuals selected to participate in the study are likely to be representative of the target population.^91^

## Future Research Needs and Opportunities

We identified a large number of natural experiment and experimental studies assessing the effects of obesity programs and policies on body weight, BMI, diet and physical activity. Our results highlight a need for future research to use better methodological standards to enhance validity and reporting. To improve the use of data systems and create linkages, we suggest that obesity researchers make greater use of the health information technology infrastructure to conduct pragmatic evaluations of obesity-related policies and programs. Since many people do not obtain longitudinal continuity care, communities need ways to collect ongoing health and behavioral information, as well as link with health care systems, community-level, school, and public health data sources to aim for completeness. Several good examples are Michigan’s Project Healthy Schools^129^ and Shape Up Somerville (MA).^94^ Michigan’s Project Healthy Schools represented a collaboration between the University of Michigan and local community organizations, including public schools, to provide an opportunity for long-term (four years reported in the included study^129^) data collection to assess the effect of a wellness program in school. Shape Up Somerville provided another example of longitudinal data collection in one community to assess the long-term effects of a multilevel childhood obesity prevention program, supported by the CDC.^94^ In the future, schools and school systems could collect health information, in particular standard weight and height measures, from their students and then link these data with other sources to increase their ability to evaluate policies and programs aimed at obesity prevention. Ongoing data collection could address the need for having “baseline” assessments available for natural experiment researchers.

To enhance validity and trustworthiness of future research, natural experiments in obesity will need to graduate their approaches from simple two-time point pre/post assessments to include approaches that capture individuals at multiple time points and use multiple comparison/control groups that each have their limitations. To improve the selection of and design of valid comparisons groups, researchers could consider approaches such as propensity score matching and regression discontinuity.^44, 103, 130^ For example, regression discontinuity methods take advantage of existing rules or cutoff points that determine receipt of the intervention of interest (e.g., individuals above some BMI threshold receive a program; those below that threshold do not). Persons just above or just below the cutoff are assumed to be very similar, so comparing these groups allows for a valid estimate of the effect of the intervention.^130^ Propensity score methods are also underused in obesity research; many studies did not even report the similarity of exposed and unexposed groups, making it hard to know whether they were or were not similar on observed confounders. Propensity score methods can help ensure the comparison of groups that are similar on observed confounders and, thus, avoid extrapolation and model dependence. Also, accompanying sensitivity analyses can be used to assess robustness of the results to a potential unobserved confounder.

Key Question 6 highlighted methodologic and analytic advances that could help to strengthen efforts to estimate the effect of programs, policies, or built environment changes on obesity prevention and control. These advances include consistent use of data dictionaries, reporting standards on linkage methods of data sources, data sources with long-term public health surveillance of obesity and health behavioral outcomes and use of study designs with multiple pre- and post- exposure time points. Because natural experiments are often conducted to evaluate feasibility, implementation barriers, future research is needed to evaluate studies in terms of implementation outcomes, as current risk of bias instruments do not address feasibility or scalability. Finally, there is growing interest in using systems science approaches to tackle complex population health problems like obesity,^131, 132^ but we do not currently have risk of bias or other methods to evaluate the quality or risks of bias in for studies that apply these new methodologies.

Finally, our review highlights the need for methodological standards in study design, analyses, and reporting of data system features and data linkages. Despite guidance from the MRC^41^ and the PCORI methodology committee,^133^ no standards like the Consolidated Standards Of Reporting Trials for trials exist for natural experiment or policy evaluation studies. We recommend standard reporting guidelines to enhance the rigor and consistency of research using natural experiments.

## Conclusions

Our systematic review identified a large heterogeneous sample of natural experiment studies and data sources that have been used to estimate the effect of programs, policies, or built environment changes on obesity prevention and control. The studies used a wide variety of outcome measures and analytic methods, often with substantial risk of bias. The findings reinforce the need for methodological and analytic advances that would strengthen efforts to improve obesity prevention and control.