# Appendix L Comparison of Two Tools for Assessing Study Risk of Bias

Table L1 Comparison of EPHPP and NOS ratings on select natural experiment studies

| EPHPP | | | | | | | Newcastle-Ottawa Scale
Author, Year | Selection Bias | Study Design | Confounders | Blinding | Data Collection Methods | Withdrawals and Drop Outs | Overall rating | Selection, Max=4 | Comparability, Max=2 | Outcome, Max =3
Barroso, 2009^1^ | M | H | H | M | M | H | H | 2 | 1 | 2
Berger-Jenkins, 2014^2^ | H | H | L | M | H | H | H | 2 | 2 | 1
Brown, 2015^3^ | L | M | L | H | L | H | H | 4 | 2 | 1
Brown, 2016^4^ | L | M | L | H | L | H | H | 4 | 1 | 2
Calise, 2013^5^ | M | H | L | L | M | M | M | 3 | 0 | 1
Cummins, 2014^6^ | M | M | L | H | L | H | H | 2 | 2 | 1
Jennings, 2012^7^ | L | M | L | H | L | H | H | 3 | 0 | 1
Just, 2014^8^ | M | H | H | M | H | H | H | 3 | 0 | 2
Kim, 2012^9^ | M | L | M | M | L | M | H | 3 | 2 | 1
King, 2014^10^ | M | L | H | H | H | M | M | 3 | 0 | 2
LaRowe, 2016^11^ | H | M | M | M | L | H | H | 4 | 1 | 3
Maddock, 2006^12^ | M | H | H | M | L | H | H | 3 | 0 | 1
Peterson, 2015^13^ | L | H | L | M | L | H | H | 3 | 1 | 2
Reger-Nash, 2008^14^ | H | M | L | M | M | H | H | 2 | 1 | 1
Restrepo, 2016^15^ | M | H | M | H | H | H | H | 2 | 2 | 1
Riis, 2012^16^ | M | H | H | M | M | H | H | 3 | 2 | 1
Taber, 2012^17^ | M | H | M | H | H | M | H | 2 | 2 | 1
Veugelers, 2005^18^ | M | L | L | M | M | L | L | 2 | 2 | 1
Webb, 2012^19^ | L | H | M | M | H | H | H | 3 | 2 | 2
Zhu, 2013^20^ | H | M | L | H | L | H | H | 2 | 0 | 1

EPHPP = Effective Public Health Practice Project; H = high risk of bias; L = low risk of bias; M = medium risk of bias; NOS=Newcastle-Ottawa Scale

## References for Appendix L

1 Barroso CS, Kelder SH, Springer AE, . Senate Bill 42: implementation and impact on physical activity in middle schools. J Adolesc Health. 2009 Sep;45(3 Suppl):S82–90. doi: 10.1016/j.jadohealth.2009.06.017. PMID: 19699442.19699442
2 Berger-Jenkins E, Rausch J, Okah E, . Evaluation of a Coordinated School-Based Obesity Prevention Program in a Hispanic Community: Choosing Healthy and Active Lifestyles for Kids/Healthy Schools Healthy Families. American Journal of Health Education. 2014;45(5):261–70. doi: 10.1080/19325037.2014.932724. PMID: 103883129.
3 Brown BB, Werner CM, Tribby CP, . Transit Use, Physical Activity, and Body Mass Index Changes: Objective Measures Associated With Complete Street Light-Rail Construction. Am J Public Health. 2015 Jul;105(7):1468–74. doi: 10.2105/ajph.2015.302561. PMID: 25973829.25973829
4 Brown BB, Smith KR, Tharp D, . A Complete Street Intervention for Walking to Transit, Nontransit Walking, and Bicycling: A Quasi-Experimental Demonstration of Increased Use. J Phys Act Health. 2016 Nov;13(11):1210–9. doi: 10.1123/jpah.2016-0066. PMID: 27334024.27334024
5 Calise TV, Heeren T, DeJong W, . Do neighborhoods make people active, or do people make active neighborhoods? Evidence from a planned community in Austin, Texas. Prev Chronic Dis. 2013 Jun 20;10:E102. doi: 10.5888/pcd10.120119. PMID: 23786909.23786909
6 Cummins S, Flint E, Matthews SA. New neighborhood grocery store increased awareness of food access but did not alter dietary habits or obesity. Health Aff (Millwood). 2014 Feb;33(2):283–91. doi: 10.1377/hlthaff.2013.0512. PMID: 24493772.24493772
7 Jennings A, Cassidy A, Winters T, . Positive effect of a targeted intervention to improve access and availability of fruit and vegetables in an area of deprivation. Health Place. 2012 Sep;18(5):1074–8. doi: 10.1016/j.healthplace.2012.05.001. PMID: 22705164.22705164
8 Just DR, Wansink B. School lunch debit card payment systems are associated with lower nutrition and higher calories. Obesity (Silver Spring). 2014 Jan;22(1):24–6. doi: 10.1002/oby.20591. PMID: 23929600.23929600
9 Kim J. Are physical education-related state policies and schools’ physical education requirement related to children’s physical activity and obesity? J Sch Health. 2012 Jun;82(6):268–76. doi: 10.1111/j.1746-1561.2012.00697.x. PMID: 22568462.22568462
10 King MH, Lederer AM, Sovinski D, . Implementation and evaluation of the HEROES initiative: a tri-state coordinated school health program to reduce childhood obesity. Health Promot Pract. 2014 May;15(3):395–405. doi: 10.1177/1524839913512835. PMID: 24334542.24334542
11 LaRowe TL, Tomayko EJ, Meinen AM, . Active Early: one-year policy intervention to increase physical activity among early care and education programs in Wisconsin. BMC Public Health. 2016 Jul 20;16:607. doi: 10.1186/s12889-016-3198-3. PMID: 27439770.27439770
12 Maddock J, Takeuchi L, Nett B, . Evaluation of a statewide program to reduce chronic disease: The Healthy Hawaii Initiative, 2000–2004. Eval Program Plann. 2006;29(3):293–300. doi: 10.1016/j.evalprogplan.2005.12.007. PMID: 2006-11996-009.
13 Peterson KE, Spadano-Gasbarro JL, Greaney ML, . Three-Year Improvements in Weight Status and Weight-Related Behaviors in Middle School Students: The Healthy Choices Study. PLoS One. 2015;10(8):e0134470. doi: 10.1371/journal.pone.0134470. PMID: 26295837.26295837
14 Reger-Nash B, Bauman A, Cooper L, . WV Walks: replication with expanded reach. J Phys Act Health. 2008 Jan;5(1):19–27. PMID: 18209251.18209251
15 Restrepo BJ. Calorie Labeling in Chain Restaurants and Body Weight: Evidence from New York. Health Econ. 2016 Jul 24doi: 10.1002/hec.3389. PMID: 27451966.27451966
16 Riis J, Grason H, Strobino D, . State school policies and youth obesity. Matern Child Health J. 2012 Apr;16 Suppl 1:S111–8. doi: 10.1007/s10995-012-1000-4. PMID: 22527761.22527761
17 Taber DR, Chriqui JF, Chaloupka FJ. Differences in nutrient intake associated with state laws regarding fat, sugar, and caloric content of competitive foods. Arch Pediatr Adolesc Med. 2012 May;166(5):452–8. doi: 10.1001/archpediatrics.2011.1839. PMID: 22566546.22566546
18 Veugelers PJ, Fitzgerald AL. Effectiveness of school programs in preventing childhood obesity: a multilevel comparison. Am J Public Health. 2005 Mar;95(3):432–5. doi: 10.2105/ajph.2004.045898. PMID: 15727972.15727972
19 Webb E, Netuveli G, Millett C. Free bus passes, use of public transport and obesity among older people in England. J Epidemiol Community Health. 2012 Feb;66(2):176–80. doi: 10.1136/jech.2011.133165. PMID: 21911850.21911850
20 Zhu X, Lu Z, Yu C, . Walkable communities: impacts on residents’ physical and social health. World Health Des 2013;7:68–75.