# Appendix K Individual Study Risk of Bias Ratings

Table K1 Individual study EPHPP risk of bias ratings

Author, year | Selection Bias | Study Design | Con-founders | Blinding | Data Collection Methods | Withdrawals and Drop Outs | Overall Rating
Natural Experiments
Anderson, 2013^1^ | M | M | M | L | H | H | H
Anthamatten, 2011^2^ | M | M | H | H | M | H | H
Azevedo, 2014^3^ | H | M | H | H | L | L | H
Barnidge, 2013^4^ | L | M | H | H | L | H | H
Barroso, 2009^5^ | M | H | M | M | L | H | H
Bauhoff, 2014^6^ | H | M | L | M | M | H | H
Bauman, 2003^7^ | M | H | H | H | H | H | H
Bere, 2010^8^ | M | M | H | M | L | M | M
Berger-Jenkins, 2014^9^ | H | M | M | M | H | H | H
Bolton, 2017^10^ | M | M | L | H | L | H | H
Bowling, 2016^11^ | M | M | H | M | L | H | H
Branas, 2011^12^ | M | M | H | M | H | H | H
Brown, 2008^13^ | H | H | H | M | M | M | H
Brown, 2015^14^ | L | M | L | H | L | H | H
Brown, 2016^15^ | L | M | L | H | L | H | H
Brown, 2016^16^ | M | M | H | H | L | H | H
Burke, 2014^17^ | M | M | H | M | L | H | H
Buscail, 2016^18^ | H | M | L | H | L | H | H
Caldwell, 2009^19^ | M | M | H | H | L | H | H
Calise, 2013^20^ | M | H | L | L | M | M | M
Camacho-Rivera, 2017^21^ | H | H | L | M | L | H | H
Capogrossi, 2016^22^ | L | M | M | M | L | M | L
Cawley, 2007^23^ | L | H | M | M | L | H | H
Cawley, 2007^24^ | L | H | H | M | L | H | H
Chen, 2015^25^ | L | M | L | M | L | H | M
Cleland, 2008^26^ | M | H | M | M | L | H | H
Coffield, 2011^27^ | H | H | M | M | H | H | H
Cohen, 2012^28^ | L | M | H | M | M | H | H
Coyle, 2009^29^ | L | M | H | H | L | H | H
Cradock, 2011^30^ | L | H | H | M | M | M | H
Cradock, 2014^31^ | M | M | M | L | L | L | L
Cullen, 2006^32^ | M | M | H | M | H | H | H
Cullen, 2008^33^ | L | M | L | H | L | H | H
Cummins, 2005^34^ | M | M | L | H | H | H | H
Cummins, 2008^35^ | H | H | L | M | M | M | H
Cummins, 2014^36^ | M | M | L | M | M | M | L
Datar, 2016^37^ | M | H | L | M | L | H | H
de Visser, 2016^38^ | H | H | H | M | L | M | H
De Cocker, 2007^39^ | M | M | L | H | L | M | M
Dill, 2014^40^ | H | M | H | M | M | H | H
Dubowitz, 2015^41^ | L | M | L | M | M | M | L
Eagle, 2013^42^ | L | M | H | H | L | H | H
Elbel, 2015^43^ | H | M | L | H | L | H | H
Elbel, 2017^44^ | M | H | L | M | M | H | H
Falbe, 2016^45^ | M | H | L | M | L | L | M
Fitzpatrick, 2017^46^ | H | M | L | M | M | M | M
Flego, 2014^47^ | L | M | L | H | L | H | H
Fogarty, 2007^48^ | M | M | H | H | L | H | H
Fox, 2009^49^ | H | H | H | M | M | M | H
Frongillo, 2017^50^ | H | H | L | H | L | H | H
Fuller, 2013^51^ | H | H | H | H | M | M | H
Fung, 2013^52^ | H | H | M | H | M | H | H
Gee, 2015^53^ | L | H | L | L | L | H | H
Gibson, 2006^54^ | M | H | M | M | L | H | H
Giles-Corti, 2013^55^ | L | M | H | M | L | L | M
Gleason, 2009^56^ | H | H | H | H | L | H | H
Goldsby, 2016^57^ | L | M | L | L | M | H | M
Goodman, 2014^58^ | L | M | L | H | M | L | M
Goodman, 2016^59^ | M | M | L | L | L | L | L
Gorely, 2011^60^ | M | M | H | H | L | M | H
Gorham, 2015^61^ | M | M | H | H | M | M | H
Harding, 2017^62^ | H | M | L | H | L | H | H
Heelan, 2015^63^ | L | M | H | M | L | L | M
Hennessy, 2014^64^ | L | M | L | L | L | H | M
Herrick, 2012^65^ | M | M | H | H | L | L | H
Hilmers, 2014^66^ | H | H | M | M | H | H | H
Hobin, 2014^67^ | M | M | M | M | H | H | H
Hobin, 2017^68^ | M | H | L | M | L | H | H
Hoelscher, 2016^69^ | M | M | L | M | L | L | L
Hoelscher, 2016^70^ | M | M | H | H | L | H | H
Howlett, 2016^71^ | L | H | H | M | L | H | H
Hu, 2016^72^ | M | M | L | M | H | M | M
Hughes, 2012^73^ | L | M | L | H | L | H | H
Hunter, 2016^74^ | H | M | H | H | M | M | H
Jennings, 2012^75^ | L | M | L | H | L | H | H
Jia, 2017^76^ | M | H | H | M | H | H | H
Johnson, 2017^77^ | M | M | L | M | H | H | H
Just, 2014^78^ | M | H | M | M | H | H | H
Kern, 2014^79^ | M | M | H | M | H | H | H
Keyte, 2012^80^ | H | H | H | M | L | M | H
Kim, 2012^81^ | M | H | H | M | M | H | H
King, 2014^82^ | M | M | H | M | H | H | H
Kubik, 2005^83^ | L | H | H | M | H | H | H
Lachapelle, 2009^84^ | H | H | H | H | H | H | H
LaRowe, 2016^85^ | H | M | M | M | L | H | H
Leung, 2013^86^ | H | H | M | L | M | H | H
Liao, 2015^87^ | M | M | H | M | L | H | H
Ling, 2014^88^ | L | M | L | H | L | H | H
Liu, 2016^89^ | M | H | M | M | H | H | H
MacDonald, 2010^90^ | M | M | L | M | L | L | L
Maddock, 2006^91^ | M | M | H | M | H | H | H
Madsen, 2011^92^ | L | H | L | M | M | M | M
Madsen, 2015^93^ | L | H | L | M | H | H | H
Malakellis, 2017^94^ | H | H | H | H | L | M | H
Masse, 2014^95^ | M | H | H | M | H | M | H
Miewald, 2012^96^ | M | H | L | H | L | H | H
Miller, 2015^97^ | M | M | H | M | L | H | H
Molitor, 2015^98^ | M | M | L | M | M | M | L
Morton, 2016^99^ | M | M | L | M | L | H | M
Mullally, 2010^100^ | L | H | H | M | M | M | H
Mumford, 2011^101^ | H | H | L | H | M | M | H
Nanney, 2014^102^ | M | M | M | M | L | M | L
Nanney, 2016^103^ | L | M | M | M | H | M | M
Benjamin Neelon, 2015^104^ | H | M | H | M | M | H | H
Nehme, 2017^105^ | H | M | L | H | M | H | H
Nguyen, 2015^106^ | L | H | L | M | L | H | H
Oh, 2015^107^ | H | H | H | M | L | H | H
Olsho, 2015^108^ | M | M | H | H | M | M | H
Panter, 2016^109^ | L | M | L | H | L | H | H
Parsons, 2014^110^ | M | H | H | M | H | H | H
Peterson, 2015^111^ | L | M | L | H | H | H | H
Powell, 2009^112^ | M | H | H | L | H | H | H
Quigg, 2012^113^ | H | M | L | M | H | L | H
Reger-Nash, 2005^114^ | L | M | L | H | L | H | H
Reger-Nash, 2008^115^ | H | M | L | M | M | H | H
Restrepo, 2016^116^ | M | H | M | H | H | H | H
Ridgers, 2007^117^ | M | M | M | M | M | L | L
Ridgers, 2007^118^ | H | M | L | M | M | L | M
Riis, 2012^119^ | M | H | H | M | L | H | H
Ritchie, 2016^120^ | M | H | L | M | L | H | H
Robles, 2017^121^ | M | H | H | H | L | H | H
Rushakoff, 2017^122^ | H | M | L | H | H | L | H
Sabia, 2016^123^ | M | H | L | M | L | H | H
Sadler, 2013^124^ | H | M | L | H | H | H | H
Sanchez-Vaznaugh, 2010^125^ | L | M | L | M | H | H | H
Schanzenbach, 2005^126^ | M | M | L | L | H | H | H
Schwartz, 2016^127^ | L | H | L | M | L | M | M
Sekhobo, 2014^128^ | L | M | H | M | L | H | H
Slater, 2014^129^ | M | H | L | H | H | H | H
Spence, 2013^130^ | H | H | H | M | M | H | H
Stephens, 2014^131^ | L | H | H | M | L | H | H
Stratton, 2005^132^ | M | M | H | H | L | M | H
Sturm, 2010^133^ | H | H | H | H | H | H | H
Sturm, 2015^134^ | M | H | L | M | H | M | H
Taber, 2011^135^ | L | H | H | M | M | M | H
Taber, 2012^136^ | M | H | M | H | H | M | H
Taber, 2012^137^ | M | M | M | M | L | M | L
Taber, 2012^138^ | M | M | H | M | M | M | M
Taber, 2013^139^ | M | M | H | M | H | H | H
Tak, 2007^140^ | M | M | H | H | L | H | H
Tak, 2009^141^ | L | M | L | H | H | M | H
Tester, 2016^142^ | L | M | L | M | L | H | M
Toussaint, 2017^143^ | M | M | L | M | L | H | M
Utter, 2016^144^ | M | H | L | M | H | H | H
Vadiveloo, 2011^145^ | L | H | L | M | M | L | M
Veugelers, 2005^146^ | M | H | M | M | M | L | M
von Hippel, 2015^147^ | M | M | H | M | M | H | H
Webb, 2012^148^ | L | H | L | M | M | M | M
Webb, 2016^149^ | M | H | L | M | M | M | M
Wells, 2005^150^ | M | M | M | M | M | M | L
West, 2011^151^ | H | H | L | H | H | H | H
Whetstone, 2012^152^ | H | H | H | M | H | H | H
Woodward-Lopez, 2010^153^ | L | M | H | M | L | M | M
Wrigley, 2003^154^ | M | M | L | H | H | M | H
Zhu, 2013^155^ | H | M | L | H | L | H | H
Zhu, 2014^156^ | H | H | L | M | M | M | M
Experimental
Alaimo, 2013^157^ | H | M | L | M | M | M | M
Anderson, 2001^158^ | L | M | L | H | L | H | H
Angelopoulos, 2009^159^ | M | L | L | M | L | L | L
Ask, 2010^160^ | M | H | H | M | M | H | H
Audrey, 2015^161^ | H | L | H | H | H | M | H
Ayala, 2013^162^ | H | L | H | M | M | M | H
Backman, 2011^163^ | L | L | H | H | L | L | H
Baker, 2016^164^ | H | M | L | M | H | H | H
Bastian, 2015^165^ | M | M | M | M | L | L | L
Bere, 2005^166^ | M | M | L | H | L | H | H
Bere, 2006^167^ | M | L | H | H | M | H | H
Bere, 2006^168^ | H | L | H | M | L | H | H
Bere, 2007^169^ | H | L | H | M | L | M | H
Beresford, 2010^170^ | M | L | L | H | M | M | M
Blum, 2008^171^ | M | L | H | M | L | L | M
Bonsergent, 2013^172^ | L | L | L | M | L | M | L
Bonvin, 2013^173^ | M | L | L | M | L | L | L
Busch, 2015^174^ | M | M | H | H | L | H | H
Caballero, 2003^175^ | L | M | H | M | L | L | M
Chomitz, 2010^176^ | L | M | L | M | M | H | M
Cochrane, 2012^177^ | H | L | L | M | L | L | M
Cohen, 2014^178^ | L | L | H | H | M | H | H
Coleman, 2012^179^ | H | L | M | M | L | M | M
Cortinez-O’Ryan, 2017^180^ | M | M | L | M | L | L | L
Crespo, 2012^181^ | M | M | L | H | L | M | M
Day, 2008^182^ | M | L | H | H | L | H | H
de Meij, 2011^183^ | L | M | L | M | L | M | L
De Coen, 2012^184^ | M | M | H | H | L | M | H
De Greef, 2016^185^ | M | L | L | H | L | H | H
Dunton, 2015^186^ | M | L | L | M | L | M | L
Dzewaltowski, 2009^187^ | M | M | L | M | L | H | M
Economos, 2007^188^ | M | M | L | M | L | M | L
Elinder, 2012^189^ | M | M | M | H | M | L | M
Eriksen, 2003^190^ | H | L | H | M | L | H | H
Ermetici, 2016^191^ | M | M | L | H | L | L | M
Esquivel, 2016^192^ | M | M | L | M | L | M | L
Evans, 2013^193^ | L | L | H | H | M | M | H
Fairclough, 2016^194^ | M | H | H | H | L | M | H
Farley, 2007^195^ | M | M | H | M | H | H | H
Farmer, 2017^196^ | H | L | L | M | L | M | M
Finch, 2014^197^ | M | L | H | M | L | H | H
Foster, 2008^198^ | M | L | L | M | L | M | L
French, 2010^199^ | M | H | H | M | M | H | H
Fu, 2016^200^ | M | H | H | M | L | H | H
Gatto, 2017^201^ | H | L | L | H | L | L | H
Geaney, 2016^202^ | M | L | L | H | M | M | M
Gittelsohn, 2010^203^ | M | M | M | M | H | H | H
Gittelsohn, 2013^204^ | M | L | M | M | M | H | M
Goetzel, 2010^205^ | M | L | L | M | M | H | M
Gustat, 2012^206^ | M | M | H | M | L | L | M
Haerens, 2006^207^ | L | L | M | H | L | H | H
Haerens, 2007^208^ | H | H | L | M | L | H | H
Hardy, 2010^209^ | H | H | L | M | M | M | H
He, 2009^210^ | M | H | L | H | L | L | H
Hendy, 2011^211^ | M | L | L | M | L | H | M
Hoefkens, 2011^212^ | M | M | M | M | L | H | M
Hollis, 2016^213^ | L | L | L | M | L | L | L
Huberty, 2011^214^ | M | L | H | H | L | H | H
Jago, 2011^215^ | H | H | L | M | L | M | H
Janssen, 2015^216^ | M | L | L | M | L | L | L
Jones, 2015^217^ | L | L | L | M | M | L | L
Jordan, 2008^218^ | M | L | H | M | M | M | M
Jurg, 2006^219^ | L | M | L | M | H | H | H
Kain, 2004^220^ | L | M | H | M | L | L | M
Kamada, 2013^221^ | M | L | M | L | M | M | L
Kastorini, 2016^222^ | H | M | L | M | H | H | H
Kloek, 2006^223^ | M | M | H | M | L | M | M
LaCaille, 2016^224^ | H | M | L | M | L | M | M
Lemon, 2010^225^ | M | L | L | M | L | M | L
Lemon, 2014^226^ | H | L | H | H | H | M | H
Lent, 2014^227^ | H | L | L | M | H | M | H
Linde, 2012^228^ | M | L | L | M | H | L | M
Llargues, 2011^229^ | L | L | L | M | L | M | L
Lorentzen, 2009^230^ | H | H | L | H | M | H | H
Lubans, 2016^231^ | M | L | L | H | M | M | M
Ludwig, 2011^232^ | L | L | L | M | L | M | L
Lv, 2014^233^ | M | H | H | H | L | M | H
Madsen, 2013^234^ | H | H | L | H | M | L | H
Madsen, 2015^235^ | M | L | L | M | M | H | M
Mead, 2013^236^ | M | H | L | M | L | M | M
Morrill, 2016^237^ | L | M | H | M | M | H | H
Murphy, 2011^238^ | H | L | H | H | M | L | H
Naylor, 2006^239^ | H | L | H | M | H | L | H
Naylor, 2008^240^ | H | H | L | H | L | L | H
Neumark-Sztainer, 2010^241^ | M | L | L | H | L | L | M
Nicklas, 2017^242^ | M | L | L | H | H | L | H
Ortega, 2016^243^ | M | M | L | M | L | M | L
Pate, 2005^244^ | L | L | L | M | M | L | L
Pbert, 2016^245^ | M | L | L | M | L | L | L
Perry, 2004^246^ | M | H | H | H | H | H | H
Ploeg, 2014^247^ | L | M | L | M | M | H | M
Pope, 2016^248^ | L | M | H | H | L | M | H
Ransley, 2007^249^ | M | L | L | M | L | M | L
Reilly, 2006^250^ | L | L | L | L | L | H | M
Reynolds, 2000^251^ | L | L | L | H | L | H | H
Ridgers, 2010^252^ | M | M | M | M | H | H | H
Rush, 2014^253^ | M | H | H | H | M | H | H
Sallis, 2003^254^ | M | L | L | H | M | L | M
Sharma, 2016^255^ | M | L | L | M | L | M | L
Shive, 2006^256^ | M | M | H | H | M | H | H
Sigmund, 2012^257^ | H | M | L | M | H | H | H
Simon, 2008^258^ | M | L | L | H | L | M | M
Steenhuis, 2004^259^ | M | L | H | H | L | H | H
Story, 2012^260^ | L | L | L | M | L | H | M
Tarp, 2016^261^ | M | L | L | H | L | M | M
Te Velde, 2008^262^ | M | H | L | M | L | M | M
Van Cauwen, 2012^263^ | H | M | L | M | L | H | H
Verloigne, 2015^264^ | H | M | H | M | L | H | H
Waters, 2017^265^ | H | L | L | M | M | H | H
Wells, 2014^266^ | M | L | L | M | M | M | L
Wendel, 2016^267^ | M | L | L | M | L | H | M
Whitt-Glover, 2011^268^ | L | H | L | M | H | M | M
Williamson, 2012^269^ | L | L | L | H | L | L | M
Wilson, 2015^270^ | M | L | L | M | M | L | L
Wright, 2012^271^ | M | L | L | M | M | L | L
Wright, 2013^272^ | M | L | L | H | L | M | M
Yildirim, 2014^273^ | M | L | L | M | L | H | M
Zhou, 2014^274^ | L | M | M | M | L | L | L
Other Study Design
Ashfield-Watt, 2007^275^ | M | M | H | H | M | L | H
Blake, 2013^276^ | M | M | L | H | H | M | H
Brownson, 2004^277^ | M | L | L | H | L | H | H
Brownson, 2005^278^ | L | M | L | H | L | H | H
Brusseau, 2016^279^ | M | M | H | M | L | H | H
Cheadle, 2012^280^ | H | M | H | M | H | H | H
De Cocker, 2011^281^ | H | H | L | M | L | H | H
de Silva-Sanigorski, 2011^282^ | H | H | H | H | M | H | H
Geaney, 2010^283^ | H | H | H | M | L | H | H
Gebel, 2011^284^ | H | M | L | M | M | M | M
Heelan, 2009^285^ | M | M | H | H | L | H | H
Huberty, 2013^286^ | H | M | H | M | L | M | H
Kim, 2012^287^ | M | M | L | H | H | M | H
Magarey, 2013^288^ | M | M | L | M | L | H | M
Naul, 2012^289^ | H | H | H | H | H | M | H
Rogers, 2013^290^ | H | H | H | M | H | H | H
Tomlin, 2012^291^ | M | M | L | H | L | H | H
Vasquez, 2016^292^ | M | M | L | M | M | L | L
Weaver, 2017^293^ | L | M | L | M | L | H | M
Whaley, 2010^294^ | L | M | L | H | L | H | H

EPHPP = Effective Public Health Practice Project; H = high risk of bias; L = low risk of bias; M = medium risk of bias

## References for Appendix K

1 Anderson LM, Aycock KE, Mihalic CA, . Geographic differences in physical education and adolescent BMI: have legal mandates made a difference? J Sch Nurs. 2013 Feb;29(1):52–60. doi: 10.1177/1059840512453602. PMID: 22815346.22815346
2 Anthamatten P, Brink L, Lampe S, . An assessment of schoolyard renovation strategies to encourage children’s physical activity. Int J Behav Nutr Phys Act. 2011 Apr 09;8:27. doi: 10.1186/1479-5868-8-27. PMID: 21477325.21477325
3 Azevedo LB, Burges Watson D, Haighton C, . The effect of dance mat exergaming systems on physical activity and health-related outcomes in secondary schools: results from a natural experiment. BMC Public Health. 2014 Sep 12;14:951. doi: 10.1186/1471-2458-14-951. PMID: 25217144.25217144
4 Barnidge EK, Hipp PR, Estlund A, . Association between community garden participation and fruit and vegetable consumption in rural Missouri. Int J Behav Nutr Phys Act. 2013 Nov 19;10:128. doi: 10.1186/1479-5868-10-128. PMID: 24252563.24252563
5 Barroso CS, Kelder SH, Springer AE, . Senate Bill 42: implementation and impact on physical activity in middle schools. J Adolesc Health. 2009 Sep;45(3 Suppl):S82–90. doi: 10.1016/j.jadohealth.2009.06.017. PMID: 19699442.19699442
6 Bauhoff S. The effect of school district nutrition policies on dietary intake and overweight: a synthetic control approach. Econ Hum Biol. 2014 Jan;12:45–55. doi: 10.1016/j.ehb.2013.06.001. PMID: 23891422.23891422
7 Bauman A, McLean G, Hurdle D, . Evaluation of the national ‘Push Play’ campaign in New Zealand--creating population awareness of physical activity. N Z Med J. 2003 Aug 08;116(1179):U535. PMID: 14513082.14513082
8 Bere E, Hilsen M, Klepp KI. Effect of the nationwide free school fruit scheme in Norway. Br J Nutr. 2010 Aug;104(4):589–94. doi: 10.1017/s0007114510000814. PMID: 20350345.20350345
9 Berger-Jenkins E, Rausch J, Okah E, . Evaluation of a Coordinated School-Based Obesity Prevention Program in a Hispanic Community: Choosing Healthy and Active Lifestyles for Kids/Healthy Schools Healthy Families. American Journal of Health Education. 2014;45(5):261–70. doi: 10.1080/19325037.2014.932724. PMID: 103883129. Language: English. Entry Date: 20140909. Revision Date: 20150820. Publication Type: Journal Article.
10 Bolton KA, Kremer P, Gibbs L, . The outcomes of health-promoting communities: being active eating well initiative-a community-based obesity prevention intervention in Victoria, Australia. Int J Obes (Lond). 2017 Apr 25doi: 10.1038/ijo.2017.73. PMID: 28321132.28321132
11 Bowling AB, Moretti M, Ringelheim K, . Healthy Foods, Healthy Families: combining incentives and exposure interventions at urban farmers’ markets to improve nutrition among recipients of US federal food assistance. Health Promot Perspect. 2016;6(1):10–6. doi: 10.15171/hpp.2016.02. PMID: 27123431.27123431
12 Branas CC, Cheney RA, MacDonald JM, . A difference-in-differences analysis of health, safety, and greening vacant urban space. Am J Epidemiol. 2011 Dec 01;174(11):1296–306. doi: 10.1093/aje/kwr273. PMID: 22079788.22079788
13 Brown AL, Khattak AJ, Rodriguez DA. Neighbourhood Types, Travel and Body Mass: A Study of New Urbanist and Suburban Neighbourhoods in the US. Urban Stud. 2008;45(4):963–88.
14 Brown BB, Werner CM, Tribby CP, . Transit Use, Physical Activity, and Body Mass Index Changes: Objective Measures Associated With Complete Street Light-Rail Construction. Am J Public Health. 2015 Jul;105(7):1468–74. doi: 10.2105/ajph.2015.302561. PMID: 25973829.25973829
15 Brown BB, Smith KR, Tharp D, . A Complete Street Intervention for Walking to Transit, Nontransit Walking, and Bicycling: A Quasi-Experimental Demonstration of Increased Use. J Phys Act Health. 2016 Nov;13(11):1210–9. doi: 10.1123/jpah.2016-0066. PMID: 27334024.27334024
16 Brown BB, Werner CM, Smith KR, . Environmental, behavioral, and psychological predictors of transit ridership: Evidence from a community intervention. J Environ Psychol. 2016 Jun;46:188–96. doi: 10.1016/j.jenvp.2016.04.010. PMID: 27672237.27672237
17 Burke RM, Meyer A, Kay C, . A holistic school-based intervention for improving health-related knowledge, body composition, and fitness in elementary school students: an evaluation of the HealthMPowers program. Int J Behav Nutr Phys Act. 2014 Jun 26;11:78. doi: 10.1186/1479-5868-11-78. PMID: 24969618.24969618
18 Buscail C, Menai M, Salanave B, . Promoting physical activity in a low-income neighborhood of the Paris suburb of Saint-Denis: effects of a community-based intervention to increase physical activity. BMC Public Health. 2016 Jul 29;16:667. doi: 10.1186/s12889-016-3360-y. PMID: 27473296.27473296
19 Caldwell EM, Miller Kobayashi M, DuBow WM, . Perceived access to fruits and vegetables associated with increased consumption. Public Health Nutr. 2009 Oct;12(10):1743–50. doi: 10.1017/s1368980008004308. PMID: 19105861.19105861
20 Calise TV, Heeren T, DeJong W, . Do neighborhoods make people active, or do people make active neighborhoods? Evidence from a planned community in Austin, Texas. Prev Chronic Dis. 2013 Jun 20;10:E102. doi: 10.5888/pcd10.120119. PMID: 23786909.23786909
21 Camacho-Rivera M, Rosenbaum E, Yama C, . Low-Income Housing Rental Assistance, Perceptions of Neighborhood Food Environment, and Dietary Patterns among Latino Adults: the AHOME Study. J Racial Ethn Health Disparities. 2017 Jun;4(3):346–53. doi: 10.1007/s40615-016-0234-z. PMID: 27129854.27129854
22 Capogrossi K, You W. The Influence of School Nutrition Programs on the Weight of Low-Income Children: A Treatment Effect Analysis. Health Econ. 2016 Jul 6doi: 10.1002/hec.3378. PMID: 27381591.27381591
23 Cawley J, Meyerhoefer C, Newhouse D. The impact of state physical education requirements on youth physical activity and overweight. Health Econ. 2007;16(12):1287–301. doi: 10.1002/hec.1218. PMID: 2007-19974-001.17328052
24 Cawley J, Meyerhoefer C, Newhouse D. The Correlation of Youth Physical Activity with State Policies. Contemporary Economic Policy. 2007;25(4):506–17. doi: http://onlinelibrary.wiley.com/journal/10.1111/%28ISSN%291465-7287. PMID: 0952344 Alternate Accession Number: EP27555031.0952344
25 Chen C, Chou S-Y, Thornton RJ. The Effect of Household Technology on Weight and Health Outcomes among Chinese Adults: Evidence from China’s ‘Home Appliances Going to the Countryside’ Policy. Journal of Human Capital. 2015 Fall;9(3):364–401. doi: http://www.jstor.org/action/showPublication?journalCode=jhumancapital. PMID: 1541217.1541217
26 Cleland V, Dwyer T, Blizzard L, . The provision of compulsory school physical activity: associations with physical activity, fitness and overweight in childhood and twenty years later. Int J Behav Nutr Phys Act. 2008 Feb 29;5:14. doi: 10.1186/1479-5868-5-14. PMID: 18312621.18312621
27 Coffield JE, Metos JM, Utz RL, . A multivariate analysis of federally mandated school wellness policies on adolescent obesity. J Adolesc Health. 2011 Oct;49(4):363–70. doi: 10.1016/j.jadohealth.2011.01.010. PMID: 21939866.21939866
28 Cohen DA, Marsh T, Williamson S, . Impact and cost-effectiveness of family Fitness Zones: a natural experiment in urban public parks. Health Place. 2012 Jan;18(1):39–45. doi: 10.1016/j.healthplace.2011.09.008. PMID: 22243905.22243905
29 Coyle KK, Potter S, Schneider D, . Distributing free fresh fruit and vegetables at school: results of a pilot outcome evaluation. Public Health Rep. 2009 Sep–Oct;124(5):660–9. doi: 10.1177/003335490912400508. PMID: 19753944.19753944
30 Cradock AL, McHugh A, Mont-Ferguson H, . Effect of school district policy change on consumption of sugar-sweetened beverages among high school students, Boston, Massachusetts, 2004–2006. Prev Chronic Dis. 2011 Jul;8(4):A74. PMID: 21672398.21672398
31 Cradock AL, Barrett JL, Carter J, . Impact of the Boston Active School Day policy to promote physical activity among children. Am J Health Promot. 2014 Jan–Feb;28(3 Suppl):S54–64. doi: 10.4278/ajhp.130430-QUAN-204. PMID: 24380467.24380467
32 Cullen KW, Watson K, Zakeri I, . Exploring changes in middle-school student lunch consumption after local school food service policy modifications. Public Health Nutr. 2006 Sep;9(6):814–20. PMID: 16925889.16925889
33 Cullen KW, Watson K, Zakeri I. Improvements in middle school student dietary intake after implementation of the Texas Public School Nutrition Policy. Am J Public Health. 2008 Jan;98(1):111–7. doi: 10.2105/ajph.2007.111765. PMID: 18048778.18048778
34 Cummins S, Petticrew M, Higgins C, . Large scale food retailing as an intervention for diet and health: quasi-experimental evaluation of a natural experiment. J Epidemiol Community Health. 2005 Dec;59(12):1035–40. doi: 10.1136/jech.2004.029843. PMID: 16286490.16286490
35 Cummins S, Findlay A, Petticrew CHM, . Reducing inequalities in health and diet: findings from a study on the impact of a food retail development. Environ Plann A 2008;40(2):402–22.
36 Cummins S, Flint E, Matthews SA. New neighborhood grocery store increased awareness of food access but did not alter dietary habits or obesity. Health Aff (Millwood). 2014 Feb;33(2):283–91. doi: 10.1377/hlthaff.2013.0512. PMID: 24493772.24493772
37 Datar A, Nicosia N. The effect of state competitive food and beverage regulations on childhood overweight and obesity. Journal of Adolescent Health. 2016doi: 10.1016/j.jadohealth.2016.09.003. PMID: 2016-54655-001.
38 de Visser R, Sylvester R, Rogers R, . Changes in School Health Program Improve Middle School Students’ Behaviors. Am J Health Behav. 2016 Sep;40(5):568–77. doi: 10.5993/ajhb.40.5.3. PMID: 27561859.27561859
39 De Cocker KA, De Bourdeaudhuij IM, Brown WJ, . Effects of “10,000 steps Ghent”: a whole-community intervention. Am J Prev Med. 2007 Dec;33(6):455–63. doi: 10.1016/j.amepre.2007.07.037. PMID: 18022061.18022061
40 Dill J, McNeil N, Broach J, . Bicycle boulevards and changes in physical activity and active transportation: findings from a natural experiment. Prev Med. 2014 Dec;69 Suppl 1:S74–8. doi: 10.1016/j.ypmed.2014.10.006. PMID: 25456802.25456802
41 Dubowitz T, Ghosh-Dastidar M, Cohen DA, . Diet And Perceptions Change With Supermarket Introduction In A Food Desert, But Not Because Of Supermarket Use. Health Aff (Millwood). 2015 Nov;34(11):1858–68. doi: 10.1377/hlthaff.2015.0667. PMID: 26526243.26526243
42 Eagle TF, Gurm R, Smith CA, . A middle school intervention to improve health behaviors and reduce cardiac risk factors. Am J Med. 2013 Oct;126(10):903–8. doi: 10.1016/j.amjmed.2013.04.019. PMID: 23932159.23932159
43 Elbel B, Moran A, Dixon LB, . Assessment of a government-subsidized supermarket in a high-need area on household food availability and children’s dietary intakes. Public Health Nutr. 2015 Oct;18(15):2881–90. doi: 10.1017/s1368980015000282. PMID: 25714993.25714993
44 Elbel B, Mijanovich T, Kiszko K, . The Introduction of a Supermarket via Tax-Credits in a Low-Income Area. Am J Health Promot. 2017 Jan;31(1):59–66. doi: 10.4278/ajhp.150217-QUAN-733. PMID: 26389982.26389982
45 Falbe J, Thompson HR, Becker CM, . Impact of the Berkeley Excise Tax on Sugar-Sweetened Beverage Consumption. Am J Public Health. 2016 Oct;106(10):1865–71. doi: 10.2105/ajph.2016.303362. PMID: 27552267.27552267
46 Fitzpatrick C, Datta GD, Henderson M, . School food environments associated with adiposity in Canadian children. Int J Obes (Lond). 2017 Mar 14doi: 10.1038/ijo.2017.39. PMID: 28186100.28186100
47 Flego A, Herbert J, Waters E, . Jamie’s Ministry of Food: quasi-experimental evaluation of immediate and sustained impacts of a cooking skills program in Australia. PLoS One. 2014;9(12):e114673. doi: 10.1371/journal.pone.0114673. PMID: 25514531.25514531
48 Fogarty AW, Antoniak M, Venn AJ, . Does participation in a population-based dietary intervention scheme have a lasting impact on fruit intake in young children? Int J Epidemiol. 2007 Oct;36(5):1080–5. doi: 10.1093/ije/dym133. PMID: 17602183.17602183
49 Fox MK, Dodd AH, Wilson A, . Association between school food environment and practices and body mass index of US public school children. J Am Diet Assoc. 2009 Feb;109(2 Suppl):S108–17. doi: 10.1016/j.jada.2008.10.065. PMID: 19166665.19166665
50 Frongillo EA, Fawcett SB, Ritchie LD, . Community Policies and Programs to Prevent Obesity and Child Adiposity. Am J Prev Med. 2017 Jul 05doi: 10.1016/j.amepre.2017.05.006. PMID: 28688728.28688728
51 Fuller D, Gauvin L, Kestens Y, . Impact evaluation of a public bicycle share program on cycling: a case example of BIXI in Montreal, Quebec. Am J Public Health. 2013 Mar;103(3):e85–92. doi: 10.2105/ajph.2012.300917. PMID: 23327280.23327280
52 Fung C, McIsaac JL, Kuhle S, . The impact of a population-level school food and nutrition policy on dietary intake and body weights of Canadian children. Prev Med. 2013 Dec;57(6):934–40. doi: 10.1016/j.ypmed.2013.07.016. PMID: 23891787.23891787
53 Gee KA. School-Based Body Mass Index Screening and Parental Notification in Late Adolescence: Evidence From Arkansas’s Act 1220. J Adolesc Health. 2015 Sep;57(3):270–6. doi: 10.1016/j.jadohealth.2015.05.007. PMID: 26115907.26115907
54 Gibson D. Long-term Food Stamp Program participation is positively related to simultaneous overweight in young daughters and obesity in mothers. J Nutr. 2006 Apr;136(4):1081–5. PMID: 16549483.16549483
55 Giles-Corti B, Bull F, Knuiman M, . The influence of urban design on neighbourhood walking following residential relocation: longitudinal results from the RESIDE study. Soc Sci Med. 2013 Jan;77:20–30. doi: 10.1016/j.socscimed.2012.10.016. PMID: 23206559.23206559
56 Gleason PM, Dodd AH. School Breakfast Program but Not School Lunch Program Participation Is Associated with Lower Body Mass Index. J Am Diet Assoc. 2009 Feb;109(2):S118–S28. doi: 10.1016/j.jada.2008.10.058. PMID: 19166666.19166666
57 Goldsby TU, George BJ, Yeager VA, . Urban Park Development and Pediatric Obesity Rates: A Quasi-Experiment Using Electronic Health Record Data. Int J Environ Res Public Health. 2016 Apr 08;13(4):411. doi: 10.3390/ijerph13040411. PMID: 27070635.27070635
58 Goodman A, Sahlqvist S, Ogilvie D. New walking and cycling routes and increased physical activity: one- and 2-year findings from the UK iConnect Study. Am J Public Health. 2014 Sep;104(9):e38–46. doi: 10.2105/ajph.2014.302059. PMID: 25033133.25033133
59 Goodman A, van Sluijs EM, Ogilvie D. Impact of offering cycle training in schools upon cycling behaviour: a natural experimental study. Int J Behav Nutr Phys Act. 2016 Mar 08;13:34. doi: 10.1186/s12966-016-0356-z. PMID: 26956383.26956383
60 Gorely T, Morris JG, Musson H, . Physical activity and body composition outcomes of the GreatFun2Run intervention at 20 month follow-up. Int J Behav Nutr Phys Act. 2011 Jul 18;8:74. doi: 10.1186/1479-5868-8-74. PMID: 21767356.21767356
61 Gorham G, Dulin-Keita A, Risica PM, . Effectiveness of Fresh to You, a Discount Fresh Fruit and Vegetable Market in Low-Income Neighborhoods, on Children’s Fruit and Vegetable Consumption, Rhode Island, 2010–2011. Prev Chronic Dis. 2015 Oct 15;12:E176. doi: 10.5888/pcd12.140583. PMID: 26469949.26469949
62 Harding MC, Bott QD, Jonas CE. The Malaekahana Path: An Ecological Model-based Intervention for Increasing Walking in Rural Hawai’i. J Phys Act Health. 2017 Jul 06:1–11. doi: 10.1123/jpah.2017-0330. PMID: 28682662.28682662
63 Heelan KA, Bartee RT, Nihiser A, . Healthier School Environment Leads to Decreases in Childhood Obesity: The Kearney Nebraska Story. Child Obes. 2015 Oct;11(5):600–7. doi: 10.1089/chi.2015.0005. PMID: 26440386.26440386
64 Hennessy E, Oh A, Agurs-Collins T, . State-level school competitive food and beverage laws are associated with children’s weight status. J Sch Health. 2014 Sep;84(9):609–16. doi: 10.1111/josh.12181. PMID: 25117896.25117896
65 Herrick H, Thompson H, Kinder J, . Use of SPARK to promote after-school physical activity. J Sch Health. 2012 Oct;82(10):457–61. doi: 10.1111/j.1746-1561.2012.00722.x. PMID: 22954164.22954164
66 Hilmers A, Chen TA, Dave JM, . Supplemental Nutrition Assistance Program participation did not help low income Hispanic women in Texas meet the dietary guidelines. Prev Med. 2014 May;62:44–8. doi: 10.1016/j.ypmed.2014.01.016. PMID: 24530319.24530319
67 Hobin E, So J, Rosella L, . Trajectories of objectively measured physical activity among secondary students in Canada in the context of a province-wide physical education policy: a longitudinal analysis. J Obes. 2014;2014:958645. doi: 10.1155/2014/958645. PMID: 24672714.24672714
68 Hobin E, Erickson T, Comte M, . Examining the impact of a province-wide physical education policy on secondary students’ physical activity as a natural experiment. Int J Behav Nutr Phys Act. 2017 Jul 19;14(1):98. doi: 10.1186/s12966-017-0550-7. PMID: 28724390.28724390
69 Hoelscher D, Ory M, Dowdy D, . Effects of funding allocation for Safe Routes to School programs on active commuting to school and related behavioral, knowledge, and psychosocial outcomes: Results from the Texas Childhood Obesity Prevention Policy Evaluation (T-COPPE) study. Environ Behav. 2016;48(1):210–29. doi: 10.1177/0013916515613541. PMID: 2016-02263-012.
70 Hoelscher DM, Moag-Stahlberg A, Ellis K, . Evaluation of a student participatory, low-intensity program to improve school wellness environment and students’ eating and activity behaviors. Int J Behav Nutr Phys Act. 2016 May 13;13:59. doi: 10.1186/s12966-016-0379-5. PMID: 27178056.27178056
71 Howlett E, Davis C, Burton S. From food desert to food oasis: The potential influence of food retailers on childhood obesity rates. Journal of Business Ethics. 2016;139(2):215–24. doi: 10.1007/s10551-015-2605-5. PMID: 2015-12722-001.
72 Hu Y, van Lenthe FJ, Judge K, . Did the English strategy reduce inequalities in health? A difference-in-difference analysis comparing England with three other European countries. BMC Public Health. 2016 Aug 24;16(1):865. doi: 10.1186/s12889-016-3505-z. PMID: 27558269.27558269
73 Hughes RJ, Edwards KL, Clarke GP, . Childhood consumption of fruit and vegetables across England: a study of 2306 6–7-year-olds in 2007. Br J Nutr. 2012 Aug;108(4):733–42. doi: 10.1017/s0007114511005939. PMID: 22321148.22321148
74 Hunter S, Leatherdale ST, Storey K, . A quasi-experimental examination of how school-based physical activity changes impact secondary school student moderate- to vigorous- intensity physical activity over time in the COMPASS study. Int J Behav Nutr Phys Act. 2016 Jul 29;13:86. doi: 10.1186/s12966-016-0411-9. PMID: 27473113.27473113
75 Jennings A, Cassidy A, Winters T, . Positive effect of a targeted intervention to improve access and availability of fruit and vegetables in an area of deprivation. Health Place. 2012 Sep;18(5):1074–8. doi: 10.1016/j.healthplace.2012.05.001. PMID: 22705164.22705164
76 Jia P, Li M, Xue H, . School environment and policies, child eating behavior and overweight/obesity in urban China: the childhood obesity study in China megacities. Int J Obes (Lond). 2017 May;41(5):813–9. doi: 10.1038/ijo.2017.2. PMID: 28074059.28074059
77 Johnson R, Robertson W, Towey M, . Changes over time in mental well-being, fruit and vegetable consumption and physical activity in a community-based lifestyle intervention: a before and after study. Public Health. 2017 May;146:118–25. doi: 10.1016/j.puhe.2017.01.012. PMID: 28404463.28404463
78 Just DR, Wansink B. School lunch debit card payment systems are associated with lower nutrition and higher calories. Obesity (Silver Spring). 2014 Jan;22(1):24–6. doi: 10.1002/oby.20591. PMID: 23929600.23929600
79 Kern E, Chan NL, Fleming DW, . Declines in student obesity prevalence associated with a prevention initiative - King County, Washington, 2012. MMWR Morb Mortal Wkly Rep. 2014 Feb 21;63(7):155–7. PMID: 24553199.24553199
80 Keyte J, Harris S, Margetts B, . Engagement with the National Healthy Schools Programme is associated with higher fruit and vegetable consumption in primary school children. J Hum Nutr Diet. 2012 Apr;25(2):155–60. doi: 10.1111/j.1365-277X.2011.01208.x. PMID: 22128770.22128770
81 Kim J. Are physical education-related state policies and schools’ physical education requirement related to children’s physical activity and obesity? J Sch Health. 2012 Jun;82(6):268–76. doi: 10.1111/j.1746-1561.2012.00697.x. PMID: 22568462.22568462
82 King MH, Lederer AM, Sovinski D, . Implementation and evaluation of the HEROES initiative: a tri-state coordinated school health program to reduce childhood obesity. Health Promot Pract. 2014 May;15(3):395–405. doi: 10.1177/1524839913512835. PMID: 24334542.24334542
83 Kubik MY, Lytle LA, Story M. Schoolwide food practices are associated with body mass index in middle school students. Arch Pediatr Adolesc Med. 2005 Dec;159(12):1111–4. doi: 10.1001/archpedi.159.12.1111. PMID: 16330732.16330732
84 Lachapelle U, Frank LD. Transit and health: mode of transport, employer-sponsored public transit pass programs, and physical activity. J Public Health Policy. 2009;30 Suppl 1:S73–94. doi: 10.1057/jphp.2008.52. PMID: 19190584.19190584
85 LaRowe TL, Tomayko EJ, Meinen AM, . Active Early: one-year policy intervention to increase physical activity among early care and education programs in Wisconsin. BMC Public Health. 2016 Jul 20;16:607. doi: 10.1186/s12889-016-3198-3. PMID: 27439770.27439770
86 Leung CW, Blumenthal SJ, Hoffnagle EE, . Associations of food stamp participation with dietary quality and obesity in children. Pediatrics. 2013 Mar;131(3):463–72. doi: 10.1542/peds.2012-0889. PMID: 23439902.23439902
87 Liao Y, Siegel PZ, Zhou H, . Reduced Disparity in Vegetable Consumption in 16 Disadvantaged Black Communities: A Successful 5-Year Community-Based Participatory Intervention. J Racial Ethn Health Disparities. 2015 Jun;2(2):211–8. doi: 10.1007/s40615-014-0065-8. PMID: 26150921.26150921
88 Ling J, King KM, Speck BJ, . Preliminary assessment of a school-based healthy lifestyle intervention among rural elementary school children. J Sch Health. 2014 Apr;84(4):247–55. doi: 10.1111/josh.12143. PMID: 24617908.24617908
89 Liu J, Kuo T, Jiang L, . Food and drink consumption among 1–5-year-old Los Angeles County children from households receiving dual SNAP and WIC v. only WIC benefits. Public Health Nutr. 2016 Sep 9:1–8. doi: 10.1017/s1368980016002329. PMID: 27609603.27609603
90 MacDonald JM, Stokes RJ, Cohen DA, . The effect of light rail transit on body mass index and physical activity. Am J Prev Med. 2010 Aug;39(2):105–12. doi: 10.1016/j.amepre.2010.03.016. PMID: 20621257.20621257
91 Maddock J, Takeuchi L, Nett B, . Evaluation of a statewide program to reduce chronic disease: The Healthy Hawaii Initiative, 2000–2004. Eval Program Plann. 2006;29(3):293–300. doi: 10.1016/j.evalprogplan.2005.12.007. PMID: 2006-11996-009.
92 Madsen KA. School-based body mass index screening and parent notification: a statewide natural experiment. Arch Pediatr Adolesc Med. 2011 Nov;165(11):987–92. doi: 10.1001/archpediatrics.2011.127. PMID: 21727262.21727262
93 Madsen KA, Cotterman C, Crawford P, . Effect of the healthy schools program on prevalence of overweight and obesity in California schools, 2006–2012. Preventing Chronic Disease: Public Health Research, Practice, and Policy. 2015;12 PMID: 2016-24674-001.
94 Malakellis M, Hoare E, Sanigorski A, . School-based systems change for obesity prevention in adolescents: outcomes of the Australian Capital Territory ‘It’s Your Move!’. Aust N Z J Public Health. 2017 Jul 27doi: 10.1111/1753-6405.12696. PMID: 28749562.28749562
95 Masse LC, de Niet-Fitzgerald JE, Watts AW, . Associations between the school food environment, student consumption and body mass index of Canadian adolescents. Int J Behav Nutr Phys Act. 2014 Mar 26;11(1):29. doi: 10.1186/1479-5868-11-29. PMID: 24666770.24666770
96 Miewald C, Holben D, Hall P. Role of a food box program in fruit and vegetable consumption and food security. Can J Diet Pract Res. 2012 Summer;73(2):59–65. doi: 10.3148/73.2.2012.59. PMID: 22668838.22668838
97 Miller HJ, Tribby CP, Brown BB, . Public transit generates new physical activity: Evidence from individual GPS and accelerometer data before and after light rail construction in a neighborhood of Salt Lake City, Utah, USA. Health Place. 2015 Nov;36:8–17. doi: 10.1016/j.healthplace.2015.08.005.26340643
98 Molitor F, Sugerman S, Yu H, . Reach of Supplemental Nutrition Assistance Program-Education (SNAP-Ed) interventions and nutrition and physical activity-related outcomes, California, 2011–2012. Prev Chronic Dis. 2015 Mar 12;12:E33. doi: 10.5888/pcd12.140449. PMID: 25764139.25764139
99 Morton KL, Corder K, Suhrcke M, . School polices, programmes and facilities, and objectively measured sedentary time, LPA and MVPA: Associations in secondary school and over the transition from primary to secondary school. Int J Behav Nutr Phys Act. 2016;13 PMID: 2016-21082-001.
100 Mullally ML, Taylor JP, Kuhle S, . A province-wide school nutrition policy and food consumption in elementary school children in Prince Edward Island. Can J Public Health. 2010 Jan–Feb;101(1):40–3. PMID: 20364537.20364537
101 Mumford KG, Contant CK, Weissman J, . Changes in physical activity and travel behaviors in residents of a mixed-use development. Am J Prev Med. 2011 Nov;41(5):504–7. doi: 10.1016/j.amepre.2011.07.016. PMID: 22011422.22011422
102 Nanney MS, MacLehose R, Kubik MY, . Recommended school policies are associated with student sugary drink and fruit and vegetable intake. Prev Med. 2014 May;62:179–81. doi: 10.1016/j.ypmed.2014.01.026. PMID: 24518003.24518003
103 Nanney MS, MacLehose RF, Kubik MY, . School Obesity Prevention Policies and Practices in Minnesota and Student Outcomes: A Longitudinal Cohort Study. Am J Prev Med. 2016 Nov;51(5):656–63. doi: 10.1016/j.amepre.2016.05.008. PMID: 27320703.27320703
104 Benjamin Neelon SE, Namenek Brouwer RJ, Ostbye T, . A community-based intervention increases physical activity and reduces obesity in school-age children in North Carolina. Child Obes. 2015 Jun;11(3):297–303. doi: 10.1089/chi.2014.0130. PMID: 25938983.25938983
105 Nehme EK, Perez A, Ranjit N, . The Effect of New Shower Facilities on Physical Activity Behaviors of Employees: A Quasi-experiment. J Phys Act Health. 2017 Feb;14(2):98–107. doi: 10.1123/jpah.2015-0418. PMID: 27775466.27775466
106 Nguyen BT, Powell LM. Supplemental nutrition assistance program participation and sugar-sweetened beverage consumption, overall and by source. Prev Med. 2015 Dec;81:82–6. doi: 10.1016/j.ypmed.2015.08.003. PMID: 26303370.26303370
107 Oh AY, Hennessy E, McSpadden KE, . Contextual Influences on Weight Status Among Impoverished Adolescents: Neighborhood Amenities for Physical Activity and State Laws for Physical Education Time Requirements. J Phys Act Health. 2015 Jun;12(6):875–8. doi: 10.1123/jpah.2013-0303. PMID: 25109235.25109235
108 Olsho LE, Payne GH, Walker DK, . Impacts of a farmers’ market incentive programme on fruit and vegetable access, purchase and consumption. Public Health Nutr. 2015 Oct;18(15):2712–21. doi: 10.1017/s1368980015001056. PMID: 25919225.25919225
109 Panter J, Heinen E, Mackett R, . Impact of New Transport Infrastructure on Walking, Cycling, and Physical Activity. Am J Prev Med. 2016 Feb;50(2):e45–53. doi: 10.1016/j.amepre.2015.09.021. PMID: 26585051.26585051
110 Parsons WG, Garcia GM, Hoffman PK. Evaluating school wellness policy in curbing childhood obesity in Anchorage, Alaska. J Sch Nurs. 2014 Oct;30(5):324–31. doi: 10.1177/1059840513513155. PMID: 24316497.24316497
111 Peterson KE, Spadano-Gasbarro JL, Greaney ML, . Three-Year Improvements in Weight Status and Weight-Related Behaviors in Middle School Students: The Healthy Choices Study. PLoS One. 2015;10(8):e0134470. doi: 10.1371/journal.pone.0134470. PMID: 26295837.26295837
112 Powell LM, Chriqui J, Chaloupka FJ. Associations between state-level soda taxes and adolescent body mass index. J Adolesc Health. 2009 Sep;45(3 Suppl):S57–63. doi: 10.1016/j.jadohealth.2009.03.003. PMID: 19699437.19699437
113 Quigg R, Reeder AI, Gray A, . The Effectiveness of a Community Playground Intervention. Journal of Urban Health-Bulletin of the New York Academy of Medicine. 2012 Feb;89(1):171–84. doi: 10.1007/s11524-011-9622-1.21959697
114 Reger-Nash B, Bauman A, Booth-Butterfield S, . Wheeling walks: evaluation of a media-based community intervention. Fam Community Health. 2005 Jan–Mar;28(1):64–78. PMID: 15625507.15625507
115 Reger-Nash B, Bauman A, Cooper L, . WV Walks: replication with expanded reach. J Phys Act Health. 2008 Jan;5(1):19–27. PMID: 18209251.18209251
116 Restrepo BJ. Calorie Labeling in Chain Restaurants and Body Weight: Evidence from New York. Health Econ. 2016 Jul 24doi: 10.1002/hec.3389. PMID: 27451966.27451966
117 Ridgers ND, Stratton G, Fairclough SJ, . Children’s physical activity levels during school recess: a quasi-experimental intervention study. Int J Behav Nutr Phys Act. 2007 May 21;4:19. doi: 10.1186/1479-5868-4-19. PMID: 17517136.17517136
118 Ridgers ND, Stratton G, Fairclough SJ, . Long-term effects of a playground markings and physical structures on children’s recess physical activity levels. Prev Med. 2007 May;44(5):393–7. doi: 10.1016/j.ypmed.2007.01.009. PMID: 17335891.17335891
119 Riis J, Grason H, Strobino D, . State school policies and youth obesity. Matern Child Health J. 2012 Apr;16 Suppl 1:S111–8. doi: 10.1007/s10995-012-1000-4. PMID: 22527761.22527761
120 Ritchie LD, Rosen NJ, Fenton K, . School Breakfast Policy Is Associated with Dietary Intake of Fourth- and Fifth-Grade Students. J Acad Nutr Diet. 2016 Mar;116(3):449–57. doi: 10.1016/j.jand.2015.08.020. PMID: 26433452.26433452
121 Robles B, Montes CE, Nobari TZ, . Dietary Behaviors among Public Health Center Clients with Electronic Benefit Transfer Access at Farmers’ Markets. J Acad Nutr Diet. 2017 Jan;117(1):58–68. doi: 10.1016/j.jand.2016.07.012. PMID: 27618576.27618576
122 Rushakoff JA, Zoughbie DE, Bui N, . Evaluation of Healthy2Go: A country store transformation project to improve the food environment and consumer choices in Appalachian Kentucky. Prev Med Rep. 2017 Sep;7:187–92. doi: 10.1016/j.pmedr.2017.06.009. PMID: 28706778.28706778
123 Sabia JJ, Nguyen TT, Rosenberg O. High School Physical Education Requirements and Youth Body Weight: New Evidence from the YRBS. Health Econ. 2016 Aug 30doi: 10.1002/hec.3399. PMID: 27576770.27576770
124 Sadler RC, Gilliland JA, Arku G. A food retail-based intervention on food security and consumption. Int J Environ Res Public Health. 2013 Aug 05;10(8):3325–46. doi: 10.3390/ijerph10083325. PMID: 23921626.23921626
125 Sanchez-Vaznaugh EV, Sanchez BN, Baek J, . ‘Competitive’ food and beverage policies: are they influencing childhood overweight trends? Health Aff (Millwood). 2010 Mar–Apr;29(3):436–46. doi: 10.1377/hlthaff.2009.0745. PMID: 20194985.20194985
126 Schanzenbach D. Do School Lunches Contribute to Childhood Obesity?: Harris School of Public Policy Studies, University of Chicago, Working Papers: 0513; 2005.
127 Schwartz AE, Leardo M, Aneja S, . Effect of a School-Based Water Intervention on Child Body Mass Index and Obesity. JAMA Pediatr. 2016 Mar;170(3):220–6. doi: 10.1001/jamapediatrics.2015.3778. PMID: 26784336.26784336
128 Sekhobo JP, Edmunds LS, Dalenius K, . Neighborhood disparities in prevalence of childhood obesity among low-income children before and after implementation of New York City child care regulations. Prev Chronic Dis. 2014;11:E181. doi: 10.5888/pcd11.140152. PMID: 25321632.25321632
129 Slater S, Chriqui J, Chaloupka FJ, . Joint use policies: are they related to adolescent behavior? Prev Med. 2014 Dec;69 Suppl 1:S37–43. doi: 10.1016/j.ypmed.2014.08.032. PMID: 25199731.25199731
130 Spence S, Delve J, Stamp E, . The impact of food and nutrient-based standards on primary school children’s lunch and total dietary intake: a natural experimental evaluation of government policy in England. PLoS One. 2013;8(10):e78298. doi: 10.1371/journal.pone.0078298. PMID: 24205190.24205190
131 Stephens RL, Xu Y, Lesesne CA, . Relationship between child care centers’ compliance with physical activity regulations and children’s physical activity, New York City, 2010. Prev Chronic Dis. 2014 Oct 16;11:E179. doi: 10.5888/pcd11.130432. PMID: 25321630.25321630
132 Stratton G, Mullan E. The effect of multicolor playground markings on children’s physical activity level during recess. Prev Med. 2005 Nov–Dec;41(5–6):828–33. doi: 10.1016/j.ypmed.2005.07.009. PMID: 16137756.16137756
133 Sturm R, Powell LM, Chriqui JF, . Soda Taxes, Soft Drink Consumption, And Children’s Body Mass Index. Health Affairs. 2010 May–Jun;29(5):1052–8. doi: 10.1377/hlthaff.2009.0061.20360173
134 Sturm R, Hattori A. Diet and obesity in Los Angeles County 2007–2012: Is there a measurable effect of the 2008 “Fast-Food Ban”? Soc Sci Med. 2015 May;133:205–11. doi: 10.1016/j.socscimed.2015.03.004. PMID: 25779774.25779774
135 Taber DR, Stevens J, Evenson KR, . State policies targeting junk food in schools: racial/ethnic differences in the effect of policy change on soda consumption. Am J Public Health. 2011 Sep;101(9):1769–75. doi: 10.2105/ajph.2011.300221. PMID: 21778484.21778484
136 Taber DR, Chriqui JF, Chaloupka FJ. Differences in nutrient intake associated with state laws regarding fat, sugar, and caloric content of competitive foods. Arch Pediatr Adolesc Med. 2012 May;166(5):452–8. doi: 10.1001/archpediatrics.2011.1839. PMID: 22566546.22566546
137 Taber DR, Chriqui JF, Perna FM, . Weight status among adolescents in States that govern competitive food nutrition content. Pediatrics. 2012 Sep;130(3):437–44. doi: 10.1542/peds.2011-3353. PMID: 22891223.22891223
138 Taber DR, Chriqui JF, Powell LM, . Banning all sugar-sweetened beverages in middle schools: reduction of in-school access and purchasing but not overall consumption. Arch Pediatr Adolesc Med. 2012 Mar;166(3):256–62. doi: 10.1001/archpediatrics.2011.200. PMID: 22064875.22064875
139 Taber DR, Chriqui JF, Perna FM, . Association between state physical education (PE) requirements and PE participation, physical activity, and body mass index change. Prev Med. 2013 Nov;57(5):629–33. doi: 10.1016/j.ypmed.2013.08.018. PMID: 23978523.23978523
140 Tak NI, Te Velde SJ, Brug J. Ethnic differences in 1-year follow-up effect of the Dutch Schoolgruiten Project - promoting fruit and vegetable consumption among primary-school children. Public Health Nutr. 2007 Dec;10(12):1497–507. doi: 10.1017/s1368980007000456. PMID: 17610757.17610757
141 Tak NI, Te Velde SJ, Brug J. Long-term effects of the Dutch Schoolgruiten Project--promoting fruit and vegetable consumption among primary-school children. Public Health Nutr. 2009 Aug;12(8):1213–23. doi: 10.1017/s1368980008003777. PMID: 18940029.18940029
142 Tester JM, Leung CW, Crawford PB. Revised WIC Food Package and Children’s Diet Quality. Pediatrics. 2016 May;137(5)doi: 10.1542/peds.2015-3557. PMID: 27244804.27244804
143 Toussaint LL, Housholder K, Janssen K, . Slowing BMI Growth Trajectories in Elementary School-Aged Children: The Northeast Iowa Food and Fitness Initiative. Fam Community Health. 2017 Jul/Sep;40(3):192–7. doi: 10.1097/fch.0000000000000151. PMID: 28525438.28525438
144 Utter J, Denny S, Dyson B. School gardens and adolescent nutrition and BMI: Results from a national, multilevel study. Prev Med. 2016 Feb;83:1–4. doi: 10.1016/j.ypmed.2015.11.022. PMID: 26657347.26657347
145 Vadiveloo MK, Dixon LB, Elbel B. Consumer purchasing patterns in response to calorie labeling legislation in New York City. Int J Behav Nutr Phys Act. 2011 May 27;8:51. doi: 10.1186/1479-5868-8-51. PMID: 21619632.21619632
146 Veugelers PJ, Fitzgerald AL. Effectiveness of school programs in preventing childhood obesity: a multilevel comparison. Am J Public Health. 2005 Mar;95(3):432–5. doi: 10.2105/ajph.2004.045898. PMID: 15727972.15727972
147 von Hippel PT, Bradbury WK. The effects of school physical education grants on obesity, fitness, and academic achievement. Prev Med. 2015 Sep;78:44–51. doi: 10.1016/j.ypmed.2015.06.011. PMID: 26163396.26163396
148 Webb E, Netuveli G, Millett C. Free bus passes, use of public transport and obesity among older people in England. J Epidemiol Community Health. 2012 Feb;66(2):176–80. doi: 10.1136/jech.2011.133165. PMID: 21911850.21911850
149 Webb E, Laverty A, Mindell J, . Free Bus Travel and Physical Activity, Gait Speed, and Adiposity in the English Longitudinal Study of Ageing. Am J Public Health. 2016 Jan;106(1):136–42. doi: 10.2105/ajph.2015.302907. PMID: 2656211826562118
150 Wells L, Nelson M. The National School Fruit Scheme produces short-term but not longer-term increases in fruit consumption in primary school children. Br J Nutr. 2005 Apr;93(4):537–42. PMID: 15946417.15946417
151 West ST, Shores KA. The impacts of building a greenway on proximate residents’ physical activity. J Phys Act Health. 2011 Nov;8(8):1092–7. PMID: 22039127.22039127
152 Whetstone LM, Kolasa KM, Collier DN. Participation in community-originated interventions is associated with positive changes in weight status and health behaviors in youth. Am J Health Promot. 2012 Sep–Oct;27(1):10–6. doi: 10.4278/ajhp.100415-QUAN-117. PMID: 22950920.22950920
153 Woodward-Lopez G, Gosliner W, Samuels SE, . Lessons learned from evaluations of California’s statewide school nutrition standards. Am J Public Health. 2010 Nov;100(11):2137–45. doi: 10.2105/ajph.2010.193490. PMID: 20864696.20864696
154 Wrigley N, Warm D, Margetts B. Deprivation, Diet, and Food-Retail Access: Findings from the Leeds ‘Food Deserts’ Study. Environ Plann A 2003;35(1):151–88.
155 Zhu X, Lu Z, Yu C, . Walkable communities: impacts on residents’ physical and social health. World Health Des 2013;7:68–75.
156 Zhu X, Yu CY, Lee C, . A retrospective study on changes in residents’ physical activities, social interactions, and neighborhood cohesion after moving to a walkable community. Prev Med. 2014 Dec;69 Suppl 1:S93–7. doi: 10.1016/j.ypmed.2014.08.013. PMID: 25158208.25158208
157 Alaimo K, Oleksyk SC, Drzal NB, . Effects of changes in lunch-time competitive foods, nutrition practices, and nutrition policies on low-income middle-school children’s diets. Child Obes. 2013 Dec;9(6):509–23. doi: 10.1089/chi.2013.0052. PMID: 24215386.24215386
158 Anderson JV, Bybee DI, Brown RM, . 5 a day fruit and vegetable intervention improves consumption in a low income population. J Am Diet Assoc. 2001 Feb;101(2):195–202. doi: 10.1016/s0002-8223(01)00052-9. PMID: 11271692.11271692
159 Angelopoulos PD, Milionis HJ, Grammatikaki E, . Changes in BMI and blood pressure after a school based intervention: the CHILDREN study. Eur J Public Health. 2009 Jun;19(3):319–25. doi: 10.1093/eurpub/ckp004. PMID: 19208697.19208697
160 Ask AS, Hernes S, Aarek I, . Serving of free school lunch to secondary-school pupils - a pilot study with health implications. Public Health Nutr. 2010 Feb;13(2):238–44. doi: 10.1017/s1368980009990772. PMID: 19650962.19650962
161 Audrey S, Procter S, Cooper A, . Employer schemes to encourage walking to work: feasibility study incorporating an exploratory randomised controlled trial. Public Health Res. 2015 Mar;3(4)doi: 10.3310/phr03040. PMID: 25763450.25763450
162 Ayala GX, Baquero B, Laraia BA, . Efficacy of a store-based environmental change intervention compared with a delayed treatment control condition on store customers’ intake of fruits and vegetables. Public Health Nutr. 2013 Nov;16(11):1953–60. doi: 10.1017/s1368980013000955. PMID: 23561842.23561842
163 Backman D, Gonzaga G, Sugerman S, . Effect of fresh fruit availability at worksites on the fruit and vegetable consumption of low-wage employees. J Nutr Educ Behav. 2011 Jul–Aug;43(4 Suppl 2):S113–21. doi: 10.1016/j.jneb.2011.04.003. PMID: 21683280.21683280
164 Baker EA, Barnidge EK, Schootman M, . Adaptation of a Modified DASH Diet to a Rural African American Community Setting. Am J Prev Med. 2016 Sep 12doi: 10.1016/j.amepre.2016.07.014. PMID: 27633485.27633485
165 Bastian KA, Maximova K, McGavock J, . Does School-Based Health Promotion Affect Physical Activity on Weekends? And, Does It Reach Those Students Most in Need of Health Promotion? PLoS One. 2015;10(10):e0137987. doi: 10.1371/journal.pone.0137987. PMID: 26488168.26488168
166 Bere E, Veierod MB, Klepp KI. The Norwegian School Fruit Programme: evaluating paid vs. no-cost subscriptions. Prev Med. 2005 Aug;41(2):463–70. doi: 10.1016/j.ypmed.2004.11.024. PMID: 15917042.15917042
167 Bere E, Veierod MB, Bjelland M, . Free school fruit--sustained effect 1 year later. Health Educ Res. 2006 Apr;21(2):268–75. doi: 10.1093/her/cyh063. PMID: 16219630.16219630
168 Bere E, Veierod MB, Bjelland M, . Outcome and process evaluation of a Norwegian school-randomized fruit and vegetable intervention: Fruits and Vegetables Make the Marks (FVMM). Health Educ Res. 2006 Apr;21(2):258–67. doi: 10.1093/her/cyh062. PMID: 16219631.16219631
169 Bere E, Veierod MB, Skare O, . Free School Fruit--sustained effect three years later. Int J Behav Nutr Phys Act. 2007 Feb 19;4:5. doi: 10.1186/1479-5868-4-5. PMID: 17309800.17309800
170 Beresford SA, Thompson B, Bishop S, . Long-term fruit and vegetable change in worksites: Seattle 5 a Day follow-up. Am J Health Behav. 2010 Nov–Dec;34(6):707–20. PMID: 20604696.20604696
171 Blum JE, Davee AM, Beaudoin CM, . Reduced availability of sugar-sweetened beverages and diet soda has a limited impact on beverage consumption patterns in Maine high school youth. J Nutr Educ Behav. 2008 Nov–Dec;40(6):341–7. doi: 10.1016/j.jneb.2007.12.004. PMID: 18984489.18984489
172 Bonsergent E, Agrinier N, Thilly N, . Overweight and obesity prevention for adolescents: a cluster randomized controlled trial in a school setting. Am J Prev Med. 2013 Jan;44(1):30–9. doi: 10.1016/j.amepre.2012.09.055. PMID: 23253647.23253647
173 Bonvin A, Barral J, Kakebeeke TH, . Effect of a governmentally-led physical activity program on motor skills in young children attending child care centers: a cluster randomized controlled trial. Int J Behav Nutr Phys Act. 2013 Jul 08;10:90. doi: 10.1186/1479-5868-10-90. PMID: 23835207.23835207
174 Busch V, De Leeuw JR, Zuithoff NP, . A Controlled Health Promoting School Study in the Netherlands: Effects After 1 and 2 Years of Intervention. Health Promot Pract. 2015 Jul;16(4):592–600. doi: 10.1177/1524839914566272. PMID: 25566994.25566994
175 Caballero B, Clay T, Davis SM, . Pathways: a school-based, randomized controlled trial for the prevention of obesity in American Indian schoolchildren. Am J Clin Nutr. 2003 Nov;78(5):1030–8. PMID: 14594792.14594792
176 Chomitz VR, McGowan RJ, Wendel JM, . Healthy Living Cambridge Kids: a community-based participatory effort to promote healthy weight and fitness. Obesity (Silver Spring). 2010 Feb;18 Suppl 1:S45–53. doi: 10.1038/oby.2009.431. PMID: 20107461.20107461
177 Cochrane T, Davey R, Iqbal Z, . NHS health checks through general practice: randomised trial of population cardiovascular risk reduction. BMC Public Health. 2012 Nov 01;12:944. doi: 10.1186/1471-2458-12-944. PMID: 23116213.23116213
178 Cohen JF, Kraak VI, Choumenkovitch SF, . The CHANGE study: a healthy-lifestyles intervention to improve rural children’s diet quality. J Acad Nutr Diet. 2014 Jan;114(1):48–53. doi: 10.1016/j.jand.2013.08.014. PMID: 24126295.24126295
179 Coleman KJ, Shordon M, Caparosa SL, . The healthy options for nutrition environments in schools (Healthy ONES) group randomized trial: using implementation models to change nutrition policy and environments in low income schools. Int J Behav Nutr Phys Act. 2012 Jun 27;9:80. doi: 10.1186/1479-5868-9-80. PMID: 22734945.22734945
180 Cortinez-O’Ryan A, Albagli A, Sadarangani KP, . Reclaiming streets for outdoor play: A process and impact evaluation of “Juega en tu Barrio” (Play in your Neighborhood), an intervention to increase physical activity and opportunities for play. PLoS One. 2017;12(7):e0180172. doi: 10.1371/journal.pone.0180172. PMID: 28671984.28671984
181 Crespo NC, Elder JP, Ayala GX, . Results of a multi-level intervention to prevent and control childhood obesity among Latino children: the Aventuras Para Ninos Study. Ann Behav Med. 2012 Feb;43(1):84–100. doi: 10.1007/s12160-011-9332-7. PMID: 22215470.22215470
182 Day ME, Strange KS, McKay HA, . Action schools! BC--Healthy Eating: effects of a whole-school model to modifying eating behaviours of elementary school children. Can J Public Health. 2008 Jul–Aug;99(4):328–31. PMID: 18767281.18767281
183 de Meij JS, Chinapaw MJ, van Stralen MM, . Effectiveness of JUMP-in, a Dutch primary school-based community intervention aimed at the promotion of physical activity. Br J Sports Med. 2011 Oct;45(13):1052–7. doi: 10.1136/bjsm.2010.075531. PMID: 21112875.21112875
184 De Coen V, De Bourdeaudhuij I, Vereecken C, . Effects of a 2-year healthy eating and physical activity intervention for 3–6-year-olds in communities of high and low socio-economic status: the POP (Prevention of Overweight among Pre-school and school children) project. Public Health Nutr. 2012 Sep;15(9):1737–45. doi: 10.1017/s1368980012000687.22397833
185 de Greeff JW, Hartman E, Mullender-Wijnsma MJ, . Effect of Physically Active Academic Lessons on Body Mass Index and Physical Fitness in Primary School Children. J Sch Health. 2016 May;86(5):346–52. doi: 10.1111/josh.12384. PMID: 27040472.27040472
186 Dunton G, Ebin VJ, Efrat MW, . The Use of Refundable Tax Credits to Increase Low-Income Children’s After-School Physical Activity Level. J Phys Act Health. 2015 Jun;12(6):840–53. doi: 10.1123/jpah.2014-0058. PMID: 25184738.25184738
187 Dzewaltowski DA, Estabrooks PA, Welk G, . Healthy youth places: a randomized controlled trial to determine the effectiveness of facilitating adult and youth leaders to promote physical activity and fruit and vegetable consumption in middle schools. Health Educ Behav. 2009 Jun;36(3):583–600. doi: 10.1177/1090198108314619. PMID: 18469366.18469366
188 Economos CD, Hyatt RR, Goldberg JP, . A community intervention reduces BMI z-score in children: Shape Up Somerville first year results. Obesity (Silver Spring). 2007 May;15(5):1325–36. doi: 10.1038/oby.2007.155. PMID: 17495210.17495210
189 Elinder LS, Heinemans N, Hagberg J, . A participatory and capacity-building approach to healthy eating and physical activity—SCIP-school: A 2-year controlled trial. Int J Behav Nutr Phys Act. 2012;9doi: 10.1186/1479-5868-9-145. PMID: 2013-04234-001.
190 Eriksen K, Haraldsdottir J, Pederson R, . Effect of a fruit and vegetable subscription in Danish schools. Public Health Nutr. 2003 Feb;6(1):57–63. doi: 10.1079/phn2002356. PMID: 12581466.12581466
191 Ermetici F, Zelaschi RF, Briganti S, . Association between a school-based intervention and adiposity outcomes in adolescents: The Italian “EAT” project. Obesity (Silver Spring). 2016 Mar;24(3):687–95. doi: 10.1002/oby.21365. PMID: 26833570.26833570
192 Esquivel M, Nigg CR, Fialkowski MK, . Head Start Wellness Policy Intervention in Hawaii: A Project of the Children’s Healthy Living Program. Child Obes. 2016 Feb;12(1):26–32. doi: 10.1089/chi.2015.0071. PMID: 26771119.26771119
193 Evans CE, Ransley JK, Christian MS, . A cluster-randomised controlled trial of a school-based fruit and vegetable intervention: Project Tomato. Public Health Nutr. 2013 Jun;16(6):1073–81. doi: 10.1017/s1368980012005290. PMID: 23237386.23237386
194 Fairclough SJ, McGrane B, Sanders G, . A non-equivalent group pilot trial of a school-based physical activity and fitness intervention for 10–11 year old english children: born to move. BMC Public Health. 2016 Aug 24;16(1):861. doi: 10.1186/s12889-016-3550-7. PMID: 27553010.27553010
195 Farley TA, Meriwether RA, Baker ET, . Safe play spaces to promote physical activity in inner-city children: results from a pilot study of an environmental intervention. Am J Public Health. 2007 Sep;97(9):1625–31. doi: 10.2105/ajph.2006.092692. PMID: 17666701.17666701
196 Farmer VL, Williams SM, Mann JI, . The effect of increasing risk and challenge in the school playground on physical activity and weight in children: a cluster randomised controlled trial (PLAY). Int J Obes (Lond). 2017 May;41(5):793–800. doi: 10.1038/ijo.2017.41. PMID: 28186099.28186099
197 Finch M, Wolfenden L, Morgan PJ, . A cluster randomized trial of a multi-level intervention, delivered by service staff, to increase physical activity of children attending center-based childcare. Prev Med. 2014 Jan;58:9–16. doi: 10.1016/j.ypmed.2013.10.004. PMID: 24145204.24145204
198 Foster GD, Sherman S, Borradaile KE, . A policy-based school intervention to prevent overweight and obesity. Pediatrics. 2008 Apr;121(4):e794–802. doi: 10.1542/peds.2007–1365. PMID: 18381508.18381508
199 French SA, Harnack LJ, Hannan PJ, . Worksite environment intervention to prevent obesity among metropolitan transit workers. Prev Med. 2010 Apr;50(4):180–5. doi: 10.1016/j.ypmed.2010.01.002. PMID: 20079369.20079369
200 Fu Y, Gao Z, Hannon JC, . Effect of the SPARK Program on Physical Activity, Cardiorespiratory Endurance, and Motivation in Middle-School Students. J Phys Act Health. 2016 May;13(5):534–42. doi: 10.1123/jpah.2015-0351. PMID: 26528889.26528889
201 Gatto NM, Martinez LC, Spruijt-Metz D, . LA sprouts randomized controlled nutrition, cooking and gardening programme reduces obesity and metabolic risk in Hispanic/Latino youth. Pediatr Obes. 2017 Feb;12(1):28–37. doi: 10.1111/ijpo.12102. PMID: 26909882.26909882
202 Geaney F, Kelly C, Di Marrazzo JS, . The effect of complex workplace dietary interventions on employees’ dietary intakes, nutrition knowledge and health status: a cluster controlled trial. Prev Med. 2016 Aug;89:76–83. doi: 10.1016/j.ypmed.2016.05.005. PMID: 27208667.27208667
203 Gittelsohn J, Vijayadeva V, Davison N, . A food store intervention trial improves caregiver psychosocial factors and children’s dietary intake in Hawaii. Obesity (Silver Spring). 2010 Feb;18 Suppl 1:S84–90. doi: 10.1038/oby.2009.436. PMID: 20107467.20107467
204 Gittelsohn J, Kim EM, He S, . A food store-based environmental intervention is associated with reduced BMI and improved psychosocial factors and food-related behaviors on the Navajo nation. J Nutr. 2013 Sep;143(9):1494–500. doi: 10.3945/jn.112.165266. PMID: 23864511.23864511
205 Goetzel RZ, Roemer EC, Pei X, . Second-year results of an obesity prevention program at the Dow Chemical Company. J Occup Environ Med. 2010 Mar;52(3):291–302. doi: 10.1097/JOM.0b013e3181d46f0b. PMID: 20190646.20190646
206 Gustat J, Rice J, Parker KM, . Effect of changes to the neighborhood built environment on physical activity in a low-income African American neighborhood. Prev Chronic Dis. 2012;9:E57. PMID: 22338597.22338597
207 Haerens L, Deforche B, Maes L, . Body mass effects of a physical activity and healthy food intervention in middle schools. Obesity (Silver Spring). 2006 May;14(5):847–54. doi: 10.1038/oby.2006.98. PMID: 16855194.16855194
208 Haerens L, De Bourdeaudhuij I, Maes L, . The effects of a middle-school healthy eating intervention on adolescents’ fat and fruit intake and soft drinks consumption. Public Health Nutr. 2007 May;10(5):443–9. doi: 10.1017/s1368980007219652. PMID: 17411463.17411463
209 Hardy LL, King L, Kelly B, . Munch and Move: evaluation of a preschool healthy eating and movement skill program. Int J Behav Nutr Phys Act. 2010 Nov 03;7:80. doi: 10.1186/1479-5868-7-80. PMID: 21047434.21047434
210 He M, Beynon C, Sangster Bouck M, . Impact evaluation of the Northern Fruit and Vegetable Pilot Programme - a cluster-randomised controlled trial. Public Health Nutr. 2009 Nov;12(11):2199–208. doi: 10.1017/s1368980009005801. PMID: 19476675.19476675
211 Hendy HM, Williams KE, Camise TS. Kid’s Choice Program improves weight management behaviors and weight status in school children. Appetite. 2011 Apr;56(2):484–94. doi: 10.1016/j.appet.2011.01.024. PMID: 21277924.21277924
212 Hoefkens C, Lachat C, Kolsteren P, . Posting point-of-purchase nutrition information in university canteens does not influence meal choice and nutrient intake. Am J Clin Nutr. 2011 Aug;94(2):562–70. doi: 10.3945/ajcn.111.013417. PMID: 21677060.21677060
213 Hollis JL, Sutherland R, Campbell L, . Effects of a ‘school-based’ physical activity intervention on adiposity in adolescents from economically disadvantaged communities: secondary outcomes of the ‘Physical Activity 4 Everyone’ RCT. Int J Obes (Lond). 2016 Oct;40(10):1486–93. doi: 10.1038/ijo.2016.107. PMID: 27430652.27430652
214 Huberty JL, Beets MW, Beighle A, . Environmental modifications to increase physical activity during recess: preliminary findings from ready for recess. J Phys Act Health. 2011 Sep;8 Suppl 2:S249–56. PMID: 21918239.21918239
215 Jago R, McMurray RG, Drews KL, . HEALTHY intervention: fitness, physical activity, and metabolic syndrome results. Med Sci Sports Exerc. 2011 Aug;43(8):1513–22. doi: 10.1249/MSS.0b013e31820c9797. PMID: 21233778.21233778
216 Janssen M, Twisk JW, Toussaint HM, . Effectiveness of the PLAYgrounds programme on PA levels during recess in 6-year-old to 12-year-old children. Br J Sports Med. 2015 Feb;49(4):259–64. doi: 10.1136/bjsports-2012-091517. PMID: 23293007.23293007
217 Jones J, Wyse R, Finch M, . Effectiveness of an intervention to facilitate the implementation of healthy eating and physical activity policies and practices in childcare services: a randomised controlled trial. Implement Sci. 2015 Oct 25;10:147. doi: 10.1186/s13012-015-0340-z. PMID: 26498746.26498746
218 Jordan KC, Erickson ED, Cox R, . Evaluation of the Gold Medal Schools program. J Am Diet Assoc. 2008 Nov;108(11):1916–20. doi: 10.1016/j.jada.2008.08.002. PMID: 18954584.18954584
219 Jurg ME, Kremers SP, Candel MJ, . A controlled trial of a school-based environmental intervention to improve physical activity in Dutch children: JUMP-in, kids in motion. Health Promot Int. 2006 Dec;21(4):320–30. doi: 10.1093/heapro/dal032. PMID: 16963784.16963784
220 Kain J, Uauy R, Albala, . School-based obesity prevention in Chilean primary school children: methodology and evaluation of a controlled study. Int J Obes Relat Metab Disord. 2004 Apr;28(4):483–93. doi: 10.1038/sj.ijo.0802611. PMID: 14993915.14993915
221 Kamada M, Kitayuguchi J, Inoue S, . A community-wide campaign to promote physical activity in middle-aged and elderly people: a cluster randomized controlled trial. Int J Behav Nutr Phys Act. 2013 Apr 09;10:44. doi: 10.1186/1479-5868-10-44. PMID: 23570536.23570536
222 Kastorini CM, Lykou A, Yannakoulia M, . The influence of a school-based intervention programme regarding adherence to a healthy diet in children and adolescents from disadvantaged areas in Greece: the DIATROFI study. J Epidemiol Community Health. 2016 Jul;70(7):671–7. doi: 10.1136/jech-2015-205680. PMID: 26763974.26763974
223 Kloek GC, van Lenthe FJ, van Nierop PW, . Impact evaluation of a Dutch community intervention to improve health-related behaviour in deprived neighbourhoods. Health Place. 2006 Dec;12(4):665–77. doi: 10.1016/j.healthplace.2005.09.002. PMID: 16253541.16253541
224 LaCaille LJ, Schultz JF, Goei R, . Go!: results from a quasi-experimental obesity prevention trial with hospital employees. BMC Public Health. 2016 Feb 19;16:171. doi: 10.1186/s12889-016-2828-0. PMID: 26893128.26893128
225 Lemon SC, Zapka J, Li W, . Step ahead a worksite obesity prevention trial among hospital employees. Am J Prev Med. 2010 Jan;38(1):27–38. doi: 10.1016/j.amepre.2009.08.028. PMID: 20117554.20117554
226 Lemon SC, Wang ML, Wedick NM, . Weight gain prevention in the school worksite setting: results of a multi-level cluster randomized trial. Prev Med. 2014 Mar;60:41–7. doi: 10.1016/j.ypmed.2013.12.010. PMID: 24345602.24345602
227 Lent MR, Vander Veur SS, McCoy TA, . A randomized controlled study of a healthy corner store initiative on the purchases of urban, low-income youth. Obesity (Silver Spring). 2014 Dec;22(12):2494–500. doi: 10.1002/oby.20878. PMID: 25311881.25311881
228 Linde JA, Nygaard KE, MacLehose RF, . HealthWorks: results of a multi-component group-randomized worksite environmental intervention trial for weight gain prevention. Int J Behav Nutr Phys Act. 2012 Feb 16;9:14. doi: 10.1186/1479-5868-9-14. PMID: 22340088.22340088
229 Llargues E, Franco R, Recasens A, . Assessment of a school-based intervention in eating habits and physical activity in school children: the AVall study. J Epidemiol Community Health. 2011 Oct;65(10):896–901. doi: 10.1136/jech.2009.102319.21398682
230 Lorentzen C, Ommundsen Y, Jenum AK, . The “Romsas in Motion” community intervention: mediating effects of psychosocial factors on forward transition in the stages of change in physical activity. Health Educ Behav. 2009 Apr;36(2):348–65. doi: 10.1177/1090198107308372. PMID: 18065570.18065570
231 Lubans DR, Smith JJ, Plotnikoff RC, . Assessing the sustained impact of a school-based obesity prevention program for adolescent boys: the ATLAS cluster randomized controlled trial. Int J Behav Nutr Phys Act. 2016 Aug 20;13:92. doi: 10.1186/s12966-016-0420-8. PMID: 27542825.27542825
232 Ludwig J, Sanbonmatsu L, Gennetian L, . Neighborhoods, obesity, and diabetes--a randomized social experiment. N Engl J Med. 2011 Oct 20;365(16):1509–19. doi: 10.1056/NEJMsa1103216. PMID: 22010917.22010917
233 Lv J, Liu QM, Ren YJ, . A community-based multilevel intervention for smoking, physical activity and diet: short-term findings from the Community Interventions for Health programme in Hangzhou, China. J Epidemiol Community Health. 2014 Apr;68(4):333–9. doi: 10.1136/jech-2013-203356. PMID: 24297972.24297972
234 Madsen K, Thompson H, Adkins A, . School-community partnerships: a cluster-randomized trial of an after-school soccer program. JAMA Pediatr. 2013 Apr;167(4):321–6. doi: 10.1001/jamapediatrics.2013.1071. PMID: 23440308.23440308
235 Madsen K, Linchey J, Gerstein D, . Energy Balance 4 Kids with Play: Results from a Two-Year Cluster-Randomized Trial. Child Obes. 2015 Aug;11(4):375–83. doi: 10.1089/chi.2015.0002. PMID: 26061799.26061799
236 Mead EL, Gittelsohn J, Roache C, . A community-based, environmental chronic disease prevention intervention to improve healthy eating psychosocial factors and behaviors in indigenous populations in the Canadian arctic. Health Education & Behavior. 2013;40(5):592–602. doi: 10.1177/1090198112467793. PMID: 2013-33808-011.23239767
237 Morrill BA, Madden GJ, Wengreen HJ, . A Randomized Controlled Trial of the Food Dudes Program: Tangible Rewards are More Effective Than Social Rewards for Increasing Short- and Long-Term Fruit and Vegetable Consumption. J Acad Nutr Diet. 2016 Apr;116(4):618–29. doi: 10.1016/j.jand.2015.07.001. PMID: 26297598.26297598
238 Murphy S, Moore GF, Tapper K, . Free healthy breakfasts in primary schools: a cluster randomised controlled trial of a policy intervention in Wales, UK. Public Health Nutr. 2011 Feb;14(2):219–26. doi: 10.1017/s1368980010001886. PMID: 20602868.20602868
239 Naylor PJ, Macdonald HM, Zebedee JA, . Lessons learned from Action Schools! BC--an ‘active school’ model to promote physical activity in elementary schools. J Sci Med Sport. 2006 Oct;9(5):413–23. doi: 10.1016/j.jsams.2006.06.013. PMID: 16884957.16884957
240 Naylor PJ, Macdonald HM, Warburton DE, . An active school model to promote physical activity in elementary schools: action schools! BC. Br J Sports Med. 2008 May;42(5):338–43. doi: 10.1136/bjsm.2007.042036. PMID: 18272538.18272538
241 Neumark-Sztainer DR, Friend SE, Flattum CF, . New moves-preventing weight-related problems in adolescent girls a group-randomized study. Am J Prev Med. 2010 Nov;39(5):421–32. doi: 10.1016/j.amepre.2010.07.017. PMID: 20965379.20965379
242 Nicklas T, Lopez S, Liu Y, . Motivational theater to increase consumption of vegetable dishes by preschool children. Int J Behav Nutr Phys Act. 2017 Feb 07;14(1):16. doi: 10.1186/s12966-017-0468-0. PMID: 28166788.28166788
243 Ortega AN, Albert SL, Chan-Golston AM, . Substantial improvements not seen in health behaviors following corner store conversions in two Latino food swamps. BMC Public Health. 2016 May 11;16:389. doi: 10.1186/s12889-016-3074-1. PMID: 27169514.27169514
244 Pate RR, Ward DS, Saunders RP, . Promotion of physical activity among high-school girls: a randomized controlled trial. Am J Public Health. 2005 Sep;95(9):1582–7. doi: 10.2105/ajph.2004.045807. PMID: 16118370.16118370
245 Pbert L, Druker S, Barton B, . A School-Based Program for Overweight and Obese Adolescents: A Randomized Controlled Trial. J Sch Health. 2016 Oct;86(10):699–708. doi: 10.1111/josh.12428. PMID: 27619760.27619760
246 Perry CL, Bishop DB, Taylor GL, . A randomized school trial of environmental strategies to encourage fruit and vegetable consumption among children. Health Educ Behav. 2004 Feb;31(1):65–76. PMID: 14768658.14768658
247 Vander Ploeg KA, McGavock J, Maximova K, . School-based health promotion and physical activity during and after school hours. Pediatrics. 2014 Feb;133(2):e371–8. doi: 10.1542/peds.2013-2383. PMID: 24420806.24420806
248 Pope M. Preventing Weight Gain in Children Who Are School Age and African-American. Pediatr Phys Ther. 2016 Summer;28(2):207–16. doi: 10.1097/pep.0000000000000243. PMID: 26914717.26914717
249 Ransley JK, Greenwood DC, Cade JE, . Does the school fruit and vegetable scheme improve children’s diet? A non-randomised controlled trial. J Epidemiol Community Health. 2007 Aug;61(8):699–703. doi: 10.1136/jech.2006.052696. PMID: 17630369.17630369
250 Reilly JJ, Kelly L, Montgomery C, . Physical activity to prevent obesity in young children: cluster randomised controlled trial. BMJ. 2006 Nov 18;333(7577):1041. doi: 10.1136/bmj.38979.623773.55. PMID: 17028105.17028105
251 Reynolds KD, Franklin FA, Binkley D, . Increasing the fruit and vegetable consumption of fourth-graders: results from the high 5 project. Prev Med. 2000 Apr;30(4):309–19. doi: 10.1006/pmed.1999.0630. PMID: 10731460.10731460
252 Ridgers ND, Fairclough SJ, Stratton G. Twelve-month effects of a playground intervention on children’s morning and lunchtime recess physical activity levels. J Phys Act Health. 2010 Mar;7(2):167–75. PMID: 20484755.20484755
253 Rush E, McLennan S, Obolonkin V, . Project Energize: whole-region primary school nutrition and physical activity programme; evaluation of body size and fitness 5 years after the randomised controlled trial. Br J Nutr. 2014 Jan 28;111(2):363–71. doi: 10.1017/s0007114513002316. PMID: 23867069.23867069
254 Sallis JF, McKenzie TL, Conway TL, . Environmental interventions for eating and physical activity: a randomized controlled trial in middle schools. Am J Prev Med. 2003 Apr;24(3):209–17. PMID: 12657338.12657338
255 Sharma SV, Markham C, Chow J, . Evaluating a school-based fruit and vegetable co-op in low-income children: A quasi-experimental study. Prev Med. 2016 Oct;91:8–17. doi: 10.1016/j.ypmed.2016.07.022. PMID: 27471022.27471022
256 Shive SE, Morris MN. Evaluation of the energize your life! Social marketing campaign pilot study to increase fruit intake among community college students. J Am Coll Health. 2006 Jul–Aug;55(1):33–9. doi: 10.3200/jach.55.1.33-40. PMID: 16889313.16889313
257 Sigmund E, El Ansari W, Sigmundova D. Does school-based physical activity decrease overweight and obesity in children aged 6–9 years? A two-year non-randomized longitudinal intervention study in the Czech Republic. BMC Public Health. 2012 Jul 29;12:570. doi: 10.1186/1471-2458-12-570. PMID: 22892226.22892226
258 Simon C, Schweitzer B, Oujaa M, . Successful overweight prevention in adolescents by increasing physical activity: a 4-year randomized controlled intervention. Int J Obes (Lond). 2008 Oct;32(10):1489–98. doi: 10.1038/ijo.2008.99. PMID: 18626482.18626482
259 Steenhuis I, Van Assema P, Van Breukelen G, . The impact of educational and environmental interventions in Dutch worksite cafeterias. Health Promot Int. 2004 Sep;19(3):335–43. doi: 10.1093/heapro/dah307. PMID: 15306618.15306618
260 Story M, Hannan PJ, Fulkerson JA, . Bright Start: Description and main outcomes from a group-randomized obesity prevention trial in American Indian children. Obesity (Silver Spring). 2012 Nov;20(11):2241–9. doi: 10.1038/oby.2012.89. PMID: 22513491.22513491
261 Tarp J, Domazet SL, Froberg K, . Effectiveness of a School-Based Physical Activity Intervention on Cognitive Performance in Danish Adolescents: LCoMotion-Learning, Cognition and Motion - A Cluster Randomized Controlled Trial. PLoS One. 2016;11(6):e0158087. doi: 10.1371/journal.pone.0158087. PMID: 27341346.27341346
262 Te Velde SJ, Brug J, Wind M, . Effects of a comprehensive fruit- and vegetable-promoting school-based intervention in three European countries: the Pro Children Study. Br J Nutr. 2008 Apr;99(4):893–903. doi: 10.1017/s000711450782513x. PMID: 17953787.17953787
263 Van Cauwenberghe E, De Bourdeaudhuij I, Maes L, . Efficacy and feasibility of lowering playground density to promote physical activity and to discourage sedentary time during recess at preschool: a pilot study. Prev Med. 2012 Oct;55(4):319–21. doi: 10.1016/j.ypmed.2012.07.014. PMID: 22846504.22846504
264 Verloigne M, Ahrens W, De Henauw S, . Process evaluation of the IDEFICS school intervention: putting the evaluation of the effect on children’s objectively measured physical activity and sedentary time in context. Obes Rev. 2015 Dec;16 Suppl 2:89–102. doi: 10.1111/obr.12353. PMID: 26707019.26707019
265 Waters E, Gibbs L, Tadic M, . Cluster randomised trial of a school-community child health promotion and obesity prevention intervention: findings from the evaluation of fun ‘n healthy in Moreland! BMC Public Health. 2017 Aug 03;18(1):92. doi: 10.1186/s12889-017-4625-9. PMID: 28774278.28774278
266 Wells NM, Myers BM, Henderson CR, Jr. School gardens and physical activity: a randomized controlled trial of low-income elementary schools. Prev Med. 2014 Dec;69 Suppl 1:S27–33. doi: 10.1016/j.ypmed.2014.10.012. PMID: 25456803.25456803
267 Wendel ML, Benden ME, Zhao H, . Stand-Biased Versus Seated Classrooms and Childhood Obesity: A Randomized Experiment in Texas. Am J Public Health. 2016 Oct;106(10):1849–54. doi: 10.2105/ajph.2016.303323. PMID: 27552276.27552276
268 Whitt-Glover MC, Ham SA, Yancey AK. Instant Recess(R): a practical tool for increasing physical activity during the school day. Prog Community Health Partnersh. 2011 Fall;5(3):289–97. doi: 10.1353/cpr.2011.0031. PMID: 22080777.22080777
269 Williamson DA, Champagne CM, Harsha DW, . Effect of an environmental school-based obesity prevention program on changes in body fat and body weight: a randomized trial. Obesity (Silver Spring). 2012 Aug;20(8):1653–61. doi: 10.1038/oby.2012.60. PMID: 22402733.22402733
270 Wilson DK, Van Horn ML, Siceloff ER, . The Results of the “Positive Action for Today’s Health” (PATH) Trial for Increasing Walking and Physical Activity in Underserved African-American Communities. Ann Behav Med. 2015 Jun;49(3):398–410. doi: 10.1007/s12160-014-9664-1. PMID: 25385203.25385203
271 Wright K, Norris K, Newman Giger J, . Improving healthy dietary behaviors, nutrition knowledge, and self-efficacy among underserved school children with parent and community involvement. Child Obes. 2012 Aug;8(4):347–56. doi: 10.1089/chi.2012.0045. PMID: 22867074.22867074
272 Wright K, Giger JN, Norris K, . Impact of a nurse-directed, coordinated school health program to enhance physical activity behaviors and reduce body mass index among minority children: a parallel-group, randomized control trial. Int J Nurs Stud. 2013 Jun;50(6):727–37. doi: 10.1016/j.ijnurstu.2012.09.004. PMID: 23021318.23021318
273 Yildirim M, Arundell L, Cerin E, . What helps children to move more at school recess and lunchtime? Mid-intervention results from Transform-Us! cluster-randomised controlled trial. Br J Sports Med. 2014 Feb;48(3):271–7. doi: 10.1136/bjsports-2013-092466. PMID: 24124036.24124036
274 Zhou Z, Ren H, Yin Z, . A policy-driven multifaceted approach for early childhood physical fitness promotion: impacts on body composition and physical fitness in young Chinese children. BMC Pediatr. 2014 May 05;14:118. doi: 10.1186/1471-2431-14-118. PMID: 24886119.24886119
275 Ashfield-Watt PA, Welch AA, Godward S, . Effect of a pilot community intervention on fruit and vegetable intakes: use of FACET (Five-a-day Community Evaluation Tool). Public Health Nutr. 2007 Jul;10(7):671–80. doi: 10.1017/s1368980007382517. PMID: 17381948.17381948
276 Blake H, Zhou D, Batt ME. Five-year workplace wellness intervention in the NHS. Perspect Public Health. 2013 Sep;133(5):262–71. doi: 10.1177/1757913913489611. PMID: 23771680.23771680
277 Brownson RC, Baker EA, Boyd RL, . A community-based approach to promoting walking in rural areas. Am J Prev Med. 2004 Jul;27(1):28–34. doi: 10.1016/j.amepre.2004.03.015. PMID: 15212772.15212772
278 Brownson RC, Hagood L, Lovegreen SL, . A multilevel ecological approach to promoting walking in rural communities. Prev Med. 2005 Nov–Dec;41(5–6):837–42. doi: 10.1016/j.ypmed.2005.09.004. PMID: 16256183.16256183
279 Brusseau TA, Hannon J, Burns R. The Effect of a Comprehensive School Physical Activity Program on Physical Activity and Health-Related Fitness in Children From Low-Income Families. J Phys Act Health. 2016 Aug;13(8):888–94. doi: 10.1123/jpah.2016-0028. PMID: 27144329.27144329
280 Cheadle A, Rauzon S, Spring R, . Kaiser Permanente ’s Community Health Initiative in Northern California: evaluation findings and lessons learned. Am J Health Promot. 2012 Nov–Dec;27(2):e59–68. doi: 10.4278/ajhp.111222-QUAN-462. PMID: 23113787.23113787
281 De Cocker KA, De Bourdeaudhuij IM, Brown WJ, . Four-year follow-up of the community intervention ‘10,000 steps Ghent’. Health Educ Res. 2011 Apr;26(2):372–80. doi: 10.1093/her/cyr015. PMID: 21393377.21393377
282 de Silva-Sanigorski A, Elea D, Bell C, . Obesity prevention in the family day care setting: impact of the Romp & Chomp intervention on opportunities for children’s physical activity and healthy eating. Child Care Health Dev. 2011 May;37(3):385–93. doi: 10.1111/j.1365-2214.2010.01205.x. PMID: 21276039.21276039
283 Geaney F, Harrington J, Perry IJ. P42 The impact of a catering initiative in determining food choices and salt intake in the public sector. Journal of Epidemiology & Community Health. 2010;64:A50-A. PMID: 104133563. Language: English. Entry Date: 20140108. Revision Date: 20150710. Publication Type: Journal Article.
284 Gebel K, Bauman AE, Reger-Nash B, . Does the environment moderate the impact of a mass media campaign to promote walking? Am J Health Promot. 2011 Sep–Oct;26(1):45–8. doi: 10.4278/ajhp.081104-ARB-269. PMID: 21879942.21879942
285 Heelan KA, Abbey BM, Donnelly JE, . Evaluation of a Walking School Bus for Promoting Physical Activity in Youth. J Phys Act Health. 2009 Sep;6(5):560–7. PMID: 19953832.19953832
286 Huberty J, Beets M, Beighle A. Effects of a policy-level intervention on children’s pedometer-determined physical activity: preliminary findings from Movin’ Afterschool. J Public Health Manag Pract. 2013 Nov–Dec;19(6):525–8. doi: 10.1097/PHH.0b013e31829465fa. PMID: 23676476.23676476
287 Kim K, Hong SA, Yun SH, . The effect of a healthy school tuck shop program on the access of students to healthy foods. Nutr Res Pract. 2012 Apr;6(2):138–45. doi: 10.4162/nrp.2012.6.2.138. PMID: 22586503.22586503
288 Magarey AM, Pettman TL, Wilson A, . Changes in Primary School Children’s Behaviour, Knowledge, Attitudes, and Environments Related to Nutrition and Physical Activity. ISRN Obes. 2013;2013:752081. doi: 10.1155/2013/752081. PMID: 24555153.24555153
289 Naul R, Schmelt D, Dreiskaemper D, . ‘Healthy children in sound communities’ (HCSC/gkgk)--a Dutch-German community-based network project to counteract obesity and physical inactivity. Fam Pract. 2012 Apr;29 Suppl 1:i110–i6. doi: 10.1093/fampra/cmr097. PMID: 22399539.22399539
290 Rogers VW, Hart PH, Motyka E, . Impact of Let’s Go! 5-2-1-0: a community-based, multisetting childhood obesity prevention program. J Pediatr Psychol. 2013 Oct;38(9):1010–20. doi: 10.1093/jpepsy/jst057. PMID: 23933841.23933841
291 Tomlin D, Naylor PJ, McKay H, . The impact of Action Schools! BC on the health of Aboriginal children and youth living in rural and remote communities in British Columbia. Int J Circumpolar Health. 2012 Mar 19;71:17999. doi: 10.3402/ijch.v71i0.17999. PMID: 22456048.22456048
292 Vasquez A, Sherwood NE, Larson N, . A novel dietary improvement strategy: examining the potential impact of community-supported agriculture membership. Public Health Nutr. 2016 Oct;19(14):2618–28. doi: 10.1017/s1368980015003638. PMID: 26857484.26857484
293 Weaver RG, Webster CA, Egan C, . Partnerships for Active Children in Elementary Schools: Outcomes of a 2-Year Pilot Study to Increase Physical Activity During the School Day. Am J Health Promot. 2017 Jan 01:890117117707289. doi: 10.1177/0890117117707289. PMID: 28482678.28482678
294 Whaley SE, McGregor S, Jiang L, . A WIC-Based Intervention to Prevent Early Childhood Overweight. J Nutr Educ Behav. 2010 May–Jun;42(3):S47–S51. doi: 10.1016/j.jneb.2010.02.010. PMID: 2039940920399409