# Appendix J Data Systems Identified by the Systematic Review

Table J1 Data systems identified by the systematic review

Author, year | Country | Primary | Secondary | Database | Custodian | Generic URL | Data Dictionary URL | Parent System URL | Data Access Link
Natural Experiment Studies
Bauhoff, 2014^1^ | USA | N | Y | California Healthy Kids Survey (CHKS) | WestEd | http://chks.wested.org/reports/ | http://chks.wested.org/administer/download/ | - | -
Bauhoff, 2014^1^ | USA | N | Y | California FITNESSGRAM Physical Fitness Test (PFT) | State of California - Department of Education | http://www.cde.ca.gov/ta/tg/pf/pftresearch.asp | https://pftdata.org/resources.aspx | http://www.cde.ca.gov/ta/tg/pf/ | http://data1.cde.ca.gov/dataquest/
Branas, 2011^2^ | USA | N | Y | PA Property Taxes | Philadelphia Bureau of Revision of Taxes | http://publicrecords.onlinesearches.com/Pennsylvania-Assessor-and-Property-Tax-Records.htm | - | - | -
Branas, 2011^2^ | USA | N | Y | Philadelphia City Map | Philadelphia Department of Licenses and Inspections | http://gsg.phila.gov/map | - | - | -
Branas, 2011^2^ | USA | N | Y | US Postal Service Records | US Postal Services | https://ribbs.usps.gov/index.cfm?page=address_info_systems | https://ribbs.usps.gov/addressing/documents/tech_guides/pubs/AIS_VIEWER_USER.PDF | - | -
Branas, 2011^2^ | USA | N | Y | Philadelphia Crime Data | Philadelphia Police Department | https://www.opendataphilly.org/dataset/crime-incidents | https://www.opendataphilly.org/dataset/crime-incidents/resource/79134de9-56fa-41f2-b529-b660aaf1539b | - | https://www.opendataphilly.org/dataset/crime-incidents/resource/c57a9de2-e300-468a-9a20-3e64e5b9b2da
Branas, 2011^2^ | USA | N | Y | Southeastern Pennsylvania Household Health Survey | Philadelphia Health Management Corporation | http://www.chdbdata.org/data-data-tools | - | - | -
Camacho-Rivera, 2017^3^ | USA | Y | N | The Affordable Housing as an Obesity Mediating | NYC-DofCityPlanning | https://www.ncbi.nlm.nih.gov/pmc/articles/PMC4074325/ | - | -
Capogrossi, 2016^4^ | USA | N | Y | Common Core of Data (CCD) | National Center for Education Statistics | https://nces.ed.gov/ccd/ccddata.asp | - | - | -
Capogrossi, 2016^4^ | USA | N | Y | Early Childhood Longitudinal Study-Kindergarten (ECLS-K) | National Center for Education and Statistics | https://nces.ed.gov/edat/ | https://nces.ed.gov/ecls/instruments2011.asp | https://nces.ed.gov/ecls/dataproducts.asp | -
Chen, 2015^5^ | China | N | Y | China Health and Nutrition Survey (CHNS) | Chinese Center for Disease Control and Prevention (CCDC) | - | http://www.cpc.unc.edu/projects/china/data/questionnaires | - | http://www.cpc.unc.edu/projects/china/data/datasets
Cleland, 2008^6^ | Australia | N | Y | Australian Schools Health and Fitness Survey (ASHFS) | Australian Government | - | - | - | -
Coffield, 2011^7^ | USA | N | Y | Utah Population Database (UPDB) | Utah State Government | Access with RGE and IRB approval: https://healthcare.utah.edu/huntsmancancerinstitute/research/updb/access.php | - | http://healthcare.utah.edu/huntsmancancerinstitute/research/updb/data/ | http://healthcare.utah.edu/huntsmancancerinstitute/research/updb/data/
Cradock, 2011^8^ | USA | N | Y | Boston Youth Survey | City of Boston and the Harvard Youth Violence Prevention Center | https://www.hsph.harvard.edu/wp-content/uploads/sites/120/2012/10/2004BYSfullreport.pdf | https://cdn1.sph.harvard.edu/wp-content/uploads/sites/120/2012/10/Inst_2006_BYS_survey_FINAL.pdf | - | https://www.hsph.harvard.edu/wp-content/uploads/sites/120/2012/10/Final_2006_BYS_Highlights_and_tables.pdf
Cummins, 2005^9^ | UK | N | Y | UK CACI Address Files | CACI Ltd. | http://www.caci.co.uk/integrated-marketing/consumer-data | http://research.caciconsult.co.uk/lifestyle-data/ | - | -
Cummins, 2008^10^ | UK | N | Y | Scottish Health Survey (Health Education Population Survey) | NHS Health Scotland | http://www.healthscotland.com/scotlands-health/population/HEPS.aspx | - | - | -
Cummins, 2014^11^ | USA | N | Y | USDA Food Atlas | US Department of Agriculture | https://www.ers.usda.gov | https://www.ers.usda.gov/data-products/ | - | https://www.ers.usda.gov/data-products/food-environment-atlas/data-access-and-documentation-downloads/
Datar, 2016^12^ | USA | N | Y | State Laws for Snack Foods and Beverages | Bridging the Gap | http://foods.bridgingthegapresearch.org/#ng12s/2012 | http://www.bridgingthegapresearch.org/_asset/44cmz6/btg_state_srts_0511_laws_codebook_14Nov11_puse-1.pdf | http://www.bridgingthegapresearch.org/research/state_obesity-related_policies/ | http://www.bridgingthegapresearch.org/_asset/kxq8n0/BTG_SRTS_hazlaw_2005_2011_with_dummyvars_03Nov11.xlsx
Fitzpatrick, 2017^13^ | Canada | N | Y | Montreal Epidemiological and Geographical Analysis of Population Health Outcomes and Neighborhood Effects | Université de Montréal | https://www.nature.com/ijo/journal/v41/n7/full/ijo201739a.html | - | -
Fitzpatrick, 2017^13^ | Canada | Y | N | Quebec Adipose and Lifestyle Investigation in Youth (Quality) Study | QUebec Adipose and Lifestyle InvesTigation in Youth | http://www.etudequalitystudy.ca/ | - | -
Fitzpatrick, 2017^13^ | Canada | N | Y | ZipCom commercial database | Tamec Inc. | http://www.zipcom.ca/en/ | | - | -
Frongillo, 2017^14^ | USA | Y | N | Community Policies and Programs | University of South Carolina | https://www.ncbi.nlm.nih.gov/pubmed/28688728 | - | -
Gee, 2015^15^ | USA | N | Y | National Survey of Children’s Health | Centers for Disease Control and Prevention | ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/slaits/nsch_2011_2012/03_Dataset | https://www.cdc.gov/nchs/data/slaits/2011nschquestionnaire.pdf | https://www.cdc.gov/nchs/slaits/nsch.htm | -
Giles-Corti, 2013^16^ | Australia | N | Y | Western Australian Liveable Neighbourhoods Guideline | Western Australian Department of Planning | https://www.planning.wa.gov.au/Liveable-neighbourhoods.aspx | - | https://www.planning.wa.gov.au/dop_pub_pdf/mrsindex.pdf | https://www.planning.wa.gov.au/dop_pub_pdf/LN_Text_update_02.pdf
Hennessy, 2014^17^ | USA | N | Y | Classification of Laws Associated with School Students | National Cancer Institute | https://class.cancer.gov/download.aspx | - | https://class.cancer.gov/ | -
Hobin, 2014^18^ | Canada | N | Y | Youth Health Survey | Canadian Cosortium | - | http://www23.statcan.gc.ca/imdb/p2SV.pl?Function=getSurvInstrumentList&Id=282165 | - | http://www23.statcan.gc.ca/imdb/p3Instr.pl?Function=assembleInstr&lang=en&Item_Id=314505
Hobin, 2017^19^ | Canada | N | Y | Manitoba (Youth Health Survey) | Partners in Planning for Healthy Living | http://partners.healthincommon.ca/tools-and-resources/youth-health-survey/ | http://partners.healthincommon.ca/wp-content/uploads/2013/01/YHS_A.pdf | - | -
Hoelscher, 2016^20^ | USA | Y | N | Texas Childhood Obesity Prevention Policy Evaluation | Texas State | - | - | https://sph.uth.edu/research/centers/dell/project.htm?project=1183cfc3-c761-442e-881f-297978d00fe8 | https://sph.uth.edu/research/centers/dell/resources/2013-Texas-Health-Perception-Survey_Report1.pdf
Howlett, 2016^21^ | USA | N | Y | County Business Patterns | Census Bureau | https://www.census.gov/programs-surveys/cbp.html | https://www2.census.gov/programs-surveys/rhfs/cbp/technical%20documentation/2015_record_layouts/county_layout_2015.txt | - | https://www.census.gov/programs-surveys/cbp/data/datasets.html
Howlett, 2016^21^ | USA | N | Y | Supplemental Nutrition Assistance Program | Department of Commerce | https://www.fns.usda.gov/pd/snap-state-activity-reports | https://www.fns.usda.gov/snap/supplemental-nutrition-assistance-program-snap | https://www.fns.usda.gov/pd/supplemental-nutrition-assistance-program-snap
Hu, 2016^22^ | Finland | N | Y | Health Behavior and Health | National Institute for Health and Welfare | https://www.thl.fi/en/web/thlfi-en/whats-new?p_p_state=maximized&p_p_mode=view&saveLastPath=0&_58_struts_action=%2Flogin%2Flogin&p_p_id=58&p_p_lifecycle=0&_58_redirect=%2Fen%2Fweb%2Fthlfi-en%2Fresearch-and-expertwork%2Fpopulation-studies%2Fhealth-behaviour-and-health-among-the-finnish-adult-population-avtk | - | https://www.thl.fi/en/web/thlfi-en/research-and-expertwork/population-studies | -
Hu, 2016^22^ | Italy | N | Y | Multipurpose Family Survey | Italian National Institute of Statistics (ISTAT) | - | https://www.istat.it/it/archivio/91926 | Health Statics => “Life styles and risk factors”=> Body mass Index: http://dati.istat.it/?lang=en | -
Hu, 2016^22^ | Italy | N | Y | Health and Health Care Utilization | Italian National Institute of Statistics (ISTAT) | http://www.istat.it/en/archive/129376 | - | - | http://www.istat.it/en/files/2014/07/pills_10_luglio_en01.pdf?title=Health+conditions+and+use+of+health+services+-+10+Jul+2014+-+Full+text.pdf
Hu, 2016^22^ | Netherland | N | Y | Permanent Survey of Living Conditions (POLS) | Netherland Government | http://statline.cbs.nl/Statweb/search/?Q=POLS-Gezondheid+1997-2009&LA=NL | - | - | http://www.jpi-dataproject.eu/Home/Database/311?topicId=7#
Hu, 2016^22^ | Netherland | N | Y | Ongoing Survey of Living Conditions (DLO) | Netherland Government | - | - | - | -
Hu, 2016^22^ | UK | N | Y | Health Survey for England | National Health Service | - | https://data.gov.uk/dataset/health_survey_for_england | https://discover.ukdataservice.ac.uk/series/?sn=2000021 | http://content.digital.nhs.uk/searchcatalogue?q=Health+Survey+for+England&area=&size=10&sort=Relevance#top
Hughes, 2012^23^ | UK | Y | N | Child and Diet Evaluation Tool | Medical Research Council - National Prevention Research Institute | http://dapa-toolkit.mrc.ac.uk/ | - | - | -
Hughes, 2012^23^ | UK | N | Y | Index of Multiple Deprivation | UK Government | https://data.gov.uk/dataset/imd_2004 | - | - | -
Hughes, 2012^23^ | UK | N | Y | Output Area Classification | UK Office for National Statistics | http://www.opengeodemographics.com/ | - | - | -
Hunter, 2016^24^ | Canada | Y | N | Cohort for obesity, marijuana use, physical activity, alcohol use, smoking and sedentary behavior | Uni of Waterloo | https://uwaterloo.ca/compass-system/compass-system-projects/compass-study | - | -
Jia, 2017^25^ | China | Y | N | Childhood Obesity Study in China Megacities | Multi-City Center for Disease Control and Prevention, China | https://www.ncbi.nlm.nih.gov/pubmed/28074059 | - | -
Just, 2014^26^ | USA | N | Y | School Nutrition Dietary Assessment Study-III (SNDA-III) | US Department of Agriculture | - | https://fns-prod.azureedge.net/sites/default/files/SNDAIII-Instruments.pdf | https://www.fns.usda.gov/school-nutrition-dietary-assessment-study-iii | https://fns-prod.azureedge.net/sites/default/files/SNDAIII-SummaryofFindings.pdf
Kern, 2014^27^ | USA | N | Y | Washington State Healthy Youth Survey (HYS) | Washington State Department of Health | http://www.doh.wa.gov/DataandStatisticalReports/DataSystems/HealthyYouthSurvey/PastSurveys | http://www.doh.wa.gov/DataandStatisticalReports/DataSystems/HealthyYouthSurvey | - | -
Kim, 2012^28^ | USA | N | Y | Physical Education-Related State Policy Classification System (PERSPCS) | National Cancer Institute (UBC: Centre for Community Child Health Research) | https://www.ncbi.nlm.nih.gov/pubmed/17884575 | - | - | http://www.ihrp.uic.edu/study/nci-physical-education-related-state-policy-classification-system-perspcs-and-school-nutrition
Kubik, 2005^29^ | USA | Y | N | Teens Eating for Energy and Nutrition at School | Penn State + Military | - | - | - | -
Lachapelle, 2009^30^ | USA | N | Y | National Household Travel Survey | US Department of Transportation - Federal Highway Administration | https://www.nationalhouseholdtravelsurvey.com/ | http://nhts.ornl.gov/2009/pub/Codebook.pdf | http://nhts.ornl.gov/ | http://nhts.ornl.gov/download.shtml
Liu, 2016^31^ | USA | N | Y | WIC Data (LA-County) | Los Angeles County | http://www.healthycity.org/maps/ | http://www.lawicdata.org/survey/ | https://www.fns.usda.gov/pd/wic-program | http://lawicdata.org/topics/obesity-2/
Liu, 2016^31^ | USA | N | Y | SNAP Supplemental | Los Angeles County | http://www.cdss.ca.gov/inforesources/Research-and-Data/CalFresh-Data-Tables | http://dpss.lacounty.gov/wps/portal/dpss/main/programs-and-services/calfresh/!ut/p/b1/04_Sj9Q1NDA1NDcyNrcw1o_Qj8pLLMtMTyzJzM9LzAHxo8zi3QwMDNz9nYKN3H2ATEf_ACdvr7BAAxMzE6CCSGQFBr5hbgaeQYbGvk7u5kYWYYaE9HvpR6Xn5CcBrQrXj0JVjMUssAIDHMDRQN_PIz83VT83KsciO8tEEQADFwf6/dl4/d5/L2dJQSEvUUt3QS80SmtFL1o2X0YwMDBHT0JTMjBFNkEwQU9TSjFVOEsxUzUw/ | https://www.fns.usda.gov/pd/supplemental-nutrition-assistance-program-snap | -
MacDonald, 2010^32^ | USA | N | Y | U.S. GDC Park Landmarks | ESRI | ESRI | - | - | -
MacDonald, 2010^32^ | USA | N | Y | Census Tiger Files | Census | https://www.census.gov/geo/maps-data/data/tiger-line.html | https://www.census.gov/geo/maps-data/data/tiger-line.html | - | -
Madsen, 2011^33^ | USA | N | Y | CDE DataQuest | The California Department of Education (CDE) | - | - | - | http://data1.cde.ca.gov/dataquest/
Malakellis, 2017^34^ | Australia | N | Y | Socio-Economic Index for Areas | ACT-IYM-Australia | http://www.health.act.gov.au/healthy-living/healthy-children-and-young-people/its-your-move | http://health.act.gov.au/sites/default/files//Questionnaire%20Planning%20Guide-webpublication%20version_AUG15.pdf | - | http://health.act.gov.au/sites/default/files//Systems%20approach%20to%20reducing%20unhealthy%20weight%20in%20Australian%20adolescents_%20ACT%20%C3%94%C3%87%C2%A3It%C3%94%C3%87%C3%96s%20Your%20Move%20%21%C3%94%C3%87%C3%98_.pdf
Masse, 2014^35^ | Canada | N | Y | Canadian Census | Statistics Canada | http://www12.statcan.ca/census-recensement/2006/dp-pd/index-eng.cfm | - | http://www12.statcan.gc.ca/census-recensement/2006/dp-pd/index-eng.cfm | http://www12.statcan.ca/datasets/Index-eng.cfm?Temporal=2006
Miewald 2012^36^ | Canada | N | Y | Canadian Community Health Survey - Household Food Security Survey Module | Government of Canada | https://www.canada.ca/en/health-canada/services/food-nutrition/food-nutrition-surveillance/health-nutrition-surveys/canadian-community-health-survey-cchs.html | https://www.canada.ca/en/health-canada/services/food-nutrition/food-nutrition-surveillance/health-nutrition-surveys/canadian-community-health-survey-cchs/canadian-community-health-survey-cycle-2-2-nutrition-2004-income-related-household-food-security-canada-health-canada-2007.html#appa | - | -
Miller, 2015^37^ | USA | Y | N | Trip Identification and Analysis System | Westat | https://www.westat.com/projects/using-gps-measure-physical-activity-levels | https://www.westat.com/expertise/statistical-research-survey-methods/survey-design | - | -
Miller, 2015^37^ | USA | N | Y | National Youth Physical Activity and Nutrition Study (NYPANS) | Centers for Disease Control and Prevention | https://www.cdc.gov/healthyyouth/data/yrbs/nypans.htm | ftp://ftp.cdc.gov/pub/data/yrbs/nypans/nypans_data_users_manual.pdf | - | -
Nanney, 2016^38^ | USA | N | Y | Minnesota Student Survey (MSS) | State of MN | http://www.health.state.mn.us/divs/chs/mss/specialreports/index.html | - | http://www.health.state.mn.us/divs/chs/mss/ | -
Nanney, 2016^38^ | USA | N | Y | The School Health Profiles (Profiles) | Centers for Disease Control and Prevention | For actual Data you need to send a request: https://www.cdc.gov/healthyyouth/data/profiles/contact.htm | https://www.cdc.gov/healthyyouth/data/profiles/questionnaires.htm | https://www.cdc.gov/healthyyouth/data/profiles/results.htm | https://www.cdc.gov/healthyschools/physicalactivity/profiles.htm
Nguyen, 2015^39^ | USA | N | Y | National Health and Nutrition Examination Survey (NHANES) | Centers for Disease Control and Prevention - National Center for Health Statistics | https://wwwn.cdc.gov/nchs/data/nhanes/survey_contents.pdf | https://www.cdc.gov/nchs/nhanes/nhanes_questionnaires.htm | - | https://wwwn.cdc.gov/nchs/nhanes/continuousnhanes/default.aspx
Olsho, 2015^40^ | USA | N | Y | NYC Community Health Survey | NYC Department of Health | http://www1.nyc.gov/site/doh/data/data-sets/community-health-survey.page | http://www1.nyc.gov/assets/doh/downloads/excel/episrv/chs-variable-crosswalk.xlsx | - | http://www1.nyc.gov/site/doh/data/data-sets/community-health-survey-public-use-data.page
Parsons, 2014^41^ | USA | N | Y | Anchorage School District’s student health data | Anchorage School District | - | - | - | http://www.asdk12.org/data/behaviordashboard/
Peterson, 2015^42^ | USA | Y | N | Community Health Information Profile (CHIP) | Massachusetts Dept. of Public Health | http://www.mass.gov/eohhs/researcher/community-health/masschip/ | - | - | -
Powell, 2009^43^ | USA | N | Y | Business list developed by Dun and Bradstreet | Dun and Bradstreet | - | - | - | -
Powell, 2009^43^ | USA | N | Y | Monitoring the Future | University of Michigan’s Institute for Social Research | http://www.monitoringthefuture.org/data/data.html | - | http://www.monitoringthefuture.org/ | -
Powell, 2009^43^ | USA | N | Y | Soda taxes | The MayaTech Corporation for the Robert Wood Johnson Foundation-supported ImpacTeen project | http://impacteen.uic.edu/statetaxdata/BTG_State_Soda_Sales_Tax_Jan012011_publuse_091911.pdf | http://impacteen.uic.edu/obesitystatedata.htm | - | -
Powell, 2009^43^ | USA | N | Y | Sales Taxes | Federation of Tax Administrators | - | - | https://www.taxadmin.org/current-tax-rates | https://www.taxadmin.org/assets/docs/Research/Rates/sales.pdf
Quig, 2012^44^ | New Zealand | N | Y | Education Review Office - Communities of Learning | New Zealand Ministry of Education | http://www.ero.govt.nz | http://www.ero.govt.nz/how-ero-reviews/ero-reviews-of-early-childhood-services-and-kohanga-reo/#self-reports-for-early-childhood-services | - | -
Quig, 2012^44^ | New Zealand | N | Y | Dunedin City Population and Demography | Dunedin City Council | http://www.dunedin.govt.nz/ | - | - | http://www.dunedin.govt.nz/your-council/long-term-plan-2015-2016/section-1-major-issues-and-strategies/city-profile/population-and-demography
Restrepo, 2016^45^ | USA | N | Y | Bureau of Labor Statistic (County-level Unemployment Rates) | US Bureau of Labor | COUNTY DATA: https://www.bls.gov/lau/ | - | - | -
Restrepo, 2016^45^ | USA | N | Y | Americans for Nonsmokers’ Rights | Americans for Nonsmokers’ Rights | http://www.no-smoke.org/goingsmokefree.php?id=519 | - | - | http://www.no-smoke.org/document.php?id=675
Restrepo, 2016^45^ | USA | N | Y | Callorie Labelling Laws | Center for Science in the Public Interest | https://cspinet.org/resource/nutrition-labeling-standard-menu-items-chain-restaurants | - | https://cspinet.org/protecting-our-health/menu-labeling | https://cspinet.org/resource/nutrition-labeling-chain-restaurants-state-and-local-lawsbillsregulations-2009-2010
Restrepo, 2016^45^ | USA | N | Y | Behavioral Risk Factor Surveillance System (BRFSS) | Centers for Disease Control and Prevention | https://www.cdc.gov/brfss/smart/smart_data.htm | https://www.cdc.gov/brfss/questionnaires/index.htm | https://www.cdc.gov/brfss/ | https://www.cdc.gov/brfss/annual_data/annual_data.htm
Restrepo, 2016^45^ | USA | N | Y | Cigarette taxes | Tax Burden on Tobacco | https://www.taxadmin.org/index.php?option=com_content&view=article&id=58:tobacco-tax-papers&catid=28:tobacco-tax&Itemid=205 | https://www.healthdata.gov/dataset/tax-burden-tobacco-volume-49-1970-2014 | https://www.taxadmin.org/assets/docs/Tobacco/papers/tax_burden_2014.pdf | -
Restrepo, 2016^45^ | USA | N | Y | Beer taxes | Brewer’s Almanac | http://www.beerinstitute.org/statistics/taxes-paid/ | - | - | -
Riis, 2012^46^ | USA | N | Y | School Nutrition-Environment State Policy Classification System | National Cancer Institute (UBC: Centre for Community Child Health Research) | https://www.ncbi.nlm.nih.gov/pubmed/17884576 | - | - | https://class.cancer.gov/data/201201/CLASS_Nutrition_SCORING_KEY_and_variable_information_132012.pdf
Robles, 2017^47^ | USA | N | Y | Los Angeles County Health and Nutrition Examination Survey | LA-County | http://publichealth.lacounty.gov/ha/ | - | http://publichealth.lacounty.gov/ha/hasurveyintro.htm
Sabia, 2016^48^ | USA | N | Y | Youth Risk Behavior Survey Suveillance – National | Centers for Disease Control and Prevention | https://nccd.cdc.gov/youthonline/App/Results.aspx?TT=B&OUT=0&SID=HS&QID=QNOBESE&LID=LL&YID=RY&LID2=&YID2=&COL=&ROW1=&ROW2=&HT=&LCT=&FS=&FR=&FG=&FI=&FP=&FSL=&FRL=&FGL=&FIL=&FPL=&PV=&TST=&C1=&C2=&QP=&DP=&VA=CI&CS=Y&SYID=&EYID=&SC=&SO= | https://www.cdc.gov/healthyyouth/data/yrbs/questionnaires.htm | https://www.cdc.gov/healthyyouth/data/topics/npao.htm | https://www.cdc.gov/healthyyouth/data/yrbs/data.htm
Sabia, 2016^48^ | USA | N | Y | Shape of the Nation Reports | National Association for Sport and Physical Education and American Heart Association | http://www.shapeamerica.org/advocacy/son/2016/upload/Shape-of-the-Nation-2016_web.pdf | - | http://www.shapeamerica.org/advocacy/son/index.cfm | -
Sabia, 2016^48^ | USA | N | Y | School Health Policy Database - State | National Association of State Boards of Education | http://www.nasbe.org/healthy_schools/hs/map.php | - | - | http://www.nasbe.org/healthy_schools/hs/search.php
Schwartz, 2016^49^ | USA | N | Y | NYC School Food Database | New York City Department of Education | - | - | - | -
Schwartz, 2016^49^ | USA | N | Y | FITNESSGRAM-NYC | The Cooper Institute | - | - | - | -
Sekhobo, 2014^50^ | USA | N | Y | The Pediatric Nutrition Surveillance System | Centers for Disease Control and Prevention | https://www.health.ny.gov/statistics/prevention/nutrition/pednss/ | - | - | -
Sturm, 2010^51^ | USA | Y | N | Bridging the Gap - Community Obesity Measures Project | RWJ Foundation | http://www.bridgingthegapresearch.org/research/community_data/ | http://www.bridgingthegapresearch.org/_asset/p5mswy/BTGCOMP_FoodStore_2012.pdf | - | -
Sturm, 2015^52^ | USA | N | Y | California Health Interview Survey | University of California Los Angeles | http://healthpolicy.ucla.edu/chis/Pages/default.aspx | http://healthpolicy.ucla.edu/chis/design/Pages/questionnairesEnglish.aspx | https://www.cdc.gov/nchs/nhis/ | http://healthpolicy.ucla.edu/chis/analyze/Pages/CHIS-Data-Documentation.aspx
Sturm, 2015^52^ | USA | N | Y | LA County Food Retail | Los Angeles County Department of Public Health | - | - | - | -
Taber, 2011^53^ | USA | N | Y | School Health Policies and Programs Study (SHPPS) | Centers for Disease Control and Prevention | - | https://www.cdc.gov/healthyyouth/data/shpps/questionnaires.htm | https://www.cdc.gov/healthyyouth/data/shpps/index.htm | https://www.cdc.gov/healthyyouth/data/shpps/data.htm
Taber, 2012^54^ | USA | N | Y | Westlaw | Thomson Reuters | - | - | - | -
Toussaint, 2017^55^ | USA | N | Y | The Northeast Iowa Food and Fitness Initiative | Kellogg Foundation Food | http://www.iowafoodandfitness.org/site/datacomm.html | http://www.iowafoodandfitness.org/site/cyclemenu.html | -
Utter, 2016^56^ | New Zealand | N | Y | Youth’12 | Adolescent Health Research Group | https://www.fmhs.auckland.ac.nz/en/faculty/adolescent-health-research-group.html | https://cdn.auckland.ac.nz/assets/fmhs/faculty/ahrg/docs/youth12-questionnaire.pdf | - | https://www.fmhs.auckland.ac.nz/assets/fmhs/faculty/ahrg/docs/2012prevalence-tables-report.pdf
von Hippel, 2015^57^ | USA | N | Y | Texas Fitness Now | Texas Government | http://tea.texas.gov/WorkArea/linkit.aspx?LinkIdentifier=id&ItemID=2147496810&libID=2147496807 | http://tea.texas.gov/Texas_Schools/Safe_and_Healthy_Schools/Physical_Fitness_Assessment_Initiative/FITNESSGRAM%C2%AE_Procedures_Manual/ | http://tea.texas.gov/Reports_and_Data/Program_Evaluations/Other_Initiatives/Program_Evaluation__Other_Initiatives/ | http://tea.texas.gov/Texas_Schools/Safe_and_Healthy_Schools/Physical_Fitness_Assessment_Initiative/Fitness_Data/
von Hippel, 2015^57^ | USA | Y | N | FitnessGram | The Cooper Institute | http://www.cooperinstitute.org/FitnessGram | http://tea.texas.gov/Texas_Schools/Safe_and_Healthy_Schools/Physical_Fitness_Assessment_Initiative/FITNESSGRAM%C2%AE_Procedures_Manual/ | - | -
Webb, 2012^58^ | UK | N | Y | English Longitudinal Study of Ageing (ELSA) | National Health Services | - | http://www.elsa-project.ac.uk/documentation | - | http://www.elsa-project.ac.uk/data_elsa
Wells, 2005^59^ | UK | N | Y | National Diet and Nutrition Survey data | United Kingdom Government (Public Health England + UK Food Standards Agency) | https://www.gov.uk/government/collections/national-diet-and-nutrition-survey | - | http://webarchive.nationalarchives.gov.uk/20130402145952/http://transparency.dh.gov.uk/category/statistics/ndns/ | -
Woodward-Lopez, 2010^60^ | USA | Y | N | School Wellness Study (SWS) | Study Team | - | - | - | -
Woodward-Lopez, 2010^60^ | USA | Y | N | the High School Study (HSS) | Study Team | - | - | - | -
Woodward-Lopez, 2010^60^ | USA | Y | N | Healthy Eating, Active Communities study (HEAC) | place-based initiative | - | - | https://portal.hud.gov/hudportal/HUD?src=/program_offices/economic_development/place_based | http://www.cssp.org/community/neighborhood-investment/place-based-initiatives
Experimental studies
Ludwig, 2011^61^ | USA | N | Y | Moving to Opportunity | Housing and Urban Development | http://www.nber.org/mtopuf/#PUF | http://www.nber.org/mtopublic/instruments.html | - | -
Perry, 2004^62^ | USA | Y | N | Nutrition Data System | University of Minnesota, Minneapolis | - | https://drive.google.com/drive/folders/0B7tgPhfpOAbTNTZ6UDBSMUV3MmM | - | -
Naylor, 2006^63^ | Canada | N | Y | School Action Inventory | British Columbia Ministry of Education | - | http://www.actionschoolsbc.ca/ | - | -
Pope, 2016^64^ | USA | Y | N | Center for Healthy Options and Community Empowerment | National Center on Minority Health and Health Disparities | https://www.nimhd.nih.gov/ | | - | -
Rush, 2014^65^ | New Zealand | Y | N | Project Energize | Waikato District Health Board | - | - | https://www.waikatodhb.health.nz/public-health-advice/project-energize/ | https://www.waikatodhb.health.nz/assets/public-health-advice/project-energize/School-engagement-in-the-Project-Energize-health-intervention-programme.pdf
Lorentzen, 2009^66^ | Norway | N | Y | Population and Demography | Statistics Norway | https://www.ssb.no/en/ | https://www.ssb.no/en/befolkning/nokkeltall/summary-tables | - | -
Evans, 2013^67^ | UK | N | Y | UK School Surveys | National Foundation of Educational Research | https://www.nfer.ac.uk/schools/school-surveys/ | https://www.nfer.ac.uk/schools/school-surveys/about-the-surveys/ | https://www.nfer.ac.uk/about-nfer/strategy-and-vision/annual-report/ | -
Other Study Designs
Cheadle, 2012^68^ | USA | Y | N | Documentation of Community Change (DOCC) | Kaiser Permanente | - | - | http://www.healzones.org/resources/ farmtoschool@caff.org | -
de Silva-Sanigorski, 2011^69^ | Australia | Y | N | Romp & Chomp | Victoria State Government, Australia | - | - | - | -
de Silva-Sanigorski, 2011^69^ | Australia | N | Y | Maternal and Child Health (MCH) Key Age and Stage (KA&S) | Victoria State Government, Australia | - | - | - | -

## References for Appendix J

1 Bauhoff S. The effect of school district nutrition policies on dietary intake and overweight: a synthetic control approach. Econ Hum Biol. 2014 Jan;12:45–55. doi: 10.1016/j.ehb.2013.06.001. PMID: 23891422.23891422
2 Branas CC, Cheney RA, MacDonald JM, . A difference-in-differences analysis of health, safety, and greening vacant urban space. Am J Epidemiol. 2011 Dec 01;174(11):1296–306. doi: 10.1093/aje/kwr273. PMID: 22079788.22079788
3 Camacho-Rivera M, Rosenbaum E, Yama C, . Low-Income Housing Rental Assistance, Perceptions of Neighborhood Food Environment, and Dietary Patterns among Latino Adults: the AHOME Study. J Racial Ethn Health Disparities. 2017 Jun;4(3):346–53. doi: 10.1007/s40615-016-0234-z. PMID: 27129854.27129854
4 Capogrossi K, You W. The Influence of School Nutrition Programs on the Weight of Low-Income Children: A Treatment Effect Analysis. Health Econ. 2016 Jul 6doi: 10.1002/hec.3378. PMID: 27381591.27381591
5 Chen C, Chou S-Y, Thornton RJ. The Effect of Household Technology on Weight and Health Outcomes among Chinese Adults: Evidence from China’s ‘Home Appliances Going to the Countryside’ Policy. Journal of Human Capital. 2015 Fall;9(3):364–401. doi: http://www.jstor.org/action/showPublication?journalCode=jhumancapital. PMID: 1541217.1541217
6 Cleland V, Dwyer T, Blizzard L, . The provision of compulsory school physical activity: associations with physical activity, fitness and overweight in childhood and twenty years later. Int J Behav Nutr Phys Act. 2008 Feb 29;5:14. doi: 10.1186/1479-5868-5-14. PMID: 18312621.18312621
7 Coffield JE, Metos JM, Utz RL, . A multivariate analysis of federally mandated school wellness policies on adolescent obesity. J Adolesc Health. 2011 Oct;49(4):363–70. doi: 10.1016/j.jadohealth.2011.01.010. PMID: 21939866.21939866
8 Cradock AL, McHugh A, Mont-Ferguson H, . Effect of school district policy change on consumption of sugar-sweetened beverages among high school students, Boston, Massachusetts, 2004–2006. Prev Chronic Dis. 2011 Jul;8(4):A74. PMID: 21672398.21672398
9 Cummins S, Petticrew M, Higgins C, . Large scale food retailing as an intervention for diet and health: quasi-experimental evaluation of a natural experiment. J Epidemiol Community Health. 2005 Dec;59(12):1035–40. doi: 10.1136/jech.2004.029843. PMID: 16286490.16286490
10 Cummins S, Findlay A, Petticrew CHM, . Reducing inequalities in health and diet: findings from a study on the impact of a food retail development. Environ Plann A 2008;40(2):402–22.
11 Cummins S, Flint E, Matthews SA. New neighborhood grocery store increased awareness of food access but did not alter dietary habits or obesity. Health Aff (Millwood). 2014 Feb;33(2):283–91. doi: 10.1377/hlthaff.2013.0512. PMID: 24493772.24493772
12 Datar A, Nicosia N. The effect of state competitive food and beverage regulations on childhood overweight and obesity. Journal of Adolescent Health. 2016doi: 10.1016/j.jadohealth.2016.09.003. PMID: 2016-54655-001.
13 Fitzpatrick C, Datta GD, Henderson M, . School food environments associated with adiposity in Canadian children. Int J Obes (Lond). 2017 Mar 14doi: 10.1038/ijo.2017.39. PMID: 28186100.28186100
14 Frongillo EA, Fawcett SB, Ritchie LD, . Community Policies and Programs to Prevent Obesity and Child Adiposity. Am J Prev Med. 2017 Jul 05doi: 10.1016/j.amepre.2017.05.006. PMID: 28688728.28688728
15 Gee KA. School-Based Body Mass Index Screening and Parental Notification in Late Adolescence: Evidence From Arkansas’s Act 1220. J Adolesc Health. 2015 Sep;57(3):270–6. doi: 10.1016/j.jadohealth.2015.05.007. PMID: 26115907.26115907
16 Giles-Corti B, Bull F, Knuiman M, . The influence of urban design on neighbourhood walking following residential relocation: longitudinal results from the RESIDE study. Soc Sci Med. 2013 Jan;77:20–30. doi: 10.1016/j.socscimed.2012.10.016. PMID: 23206559.23206559
17 Hennessy E, Oh A, Agurs-Collins T, . State-level school competitive food and beverage laws are associated with children’s weight status. J Sch Health. 2014 Sep;84(9):609–16. doi: 10.1111/josh.12181. PMID: 25117896.25117896
18 Hobin E, So J, Rosella L, . Trajectories of objectively measured physical activity among secondary students in Canada in the context of a province-wide physical education policy: a longitudinal analysis. J Obes. 2014;2014:958645. doi: 10.1155/2014/958645. PMID: 24672714.24672714
19 Hobin E, Erickson T, Comte M, . Examining the impact of a province-wide physical education policy on secondary students’ physical activity as a natural experiment. Int J Behav Nutr Phys Act. 2017 Jul 19;14(1):98. doi: 10.1186/s12966-017-0550-7. PMID: 28724390.28724390
20 Hoelscher D, Ory M, Dowdy D, . Effects of funding allocation for Safe Routes to School programs on active commuting to school and related behavioral, knowledge, and psychosocial outcomes: Results from the Texas Childhood Obesity Prevention Policy Evaluation (T-COPPE) study. Environ Behav. 2016;48(1):210–29. doi: 10.1177/0013916515613541. PMID: 2016-02263-012.
21 Howlett E, Davis C, Burton S. From food desert to food oasis: The potential influence of food retailers on childhood obesity rates. Journal of Business Ethics. 2016;139(2):215–24. doi: 10.1007/s10551-015-2605-5. PMID: 2015-12722-001.
22 Hu Y, van Lenthe FJ, Judge K, . Did the English strategy reduce inequalities in health? A difference-in-difference analysis comparing England with three other European countries. BMC Public Health. 2016 Aug 24;16(1):865. doi: 10.1186/s12889-016-3505-z. PMID: 27558269.27558269
23 Hughes RJ, Edwards KL, Clarke GP, . Childhood consumption of fruit and vegetables across England: a study of 2306 6–7-year-olds in 2007. Br J Nutr. 2012 Aug;108(4):733–42. doi: 10.1017/s0007114511005939. PMID: 22321148.22321148
24 Hunter S, Leatherdale ST, Storey K, . A quasi-experimental examination of how school-based physical activity changes impact secondary school student moderate- to vigorous- intensity physical activity over time in the COMPASS study. Int J Behav Nutr Phys Act. 2016 Jul 29;13:86. doi: 10.1186/s12966-016-0411-9. PMID: 27473113.27473113
25 Jia P, Li M, Xue H, . School environment and policies, child eating behavior and overweight/obesity in urban China: the childhood obesity study in China megacities. Int J Obes (Lond). 2017 May;41(5):813–9. doi: 10.1038/ijo.2017.2. PMID: 28074059.28074059
26 Just DR, Wansink B. School lunch debit card payment systems are associated with lower nutrition and higher calories. Obesity (Silver Spring). 2014 Jan;22(1):24–6. doi: 10.1002/oby.20591. PMID: 23929600.23929600
27 Kern E, Chan NL, Fleming DW, . Declines in student obesity prevalence associated with a prevention initiative - King County, Washington, 2012. MMWR Morb Mortal Wkly Rep. 2014 Feb 21;63(7):155–7. PMID: 24553199.24553199
28 Kim J. Are physical education-related state policies and schools’ physical education requirement related to children’s physical activity and obesity? J Sch Health. 2012 Jun;82(6):268–76. doi: 10.1111/j.1746-1561.2012.00697.x. PMID: 22568462.22568462
29 Kubik MY, Lytle LA, Story M. Schoolwide food practices are associated with body mass index in middle school students. Arch Pediatr Adolesc Med. 2005 Dec;159(12):1111–4. doi: 10.1001/archpedi.159.12.1111. PMID: 16330732.16330732
30 Lachapelle U, Frank LD. Transit and health: mode of transport, employer-sponsored public transit pass programs, and physical activity. J Public Health Policy. 2009;30 Suppl 1:S73–94. doi: 10.1057/jphp.2008.52. PMID: 19190584.19190584
31 Liu J, Kuo T, Jiang L, . Food and drink consumption among 1–5-year-old Los Angeles County children from households receiving dual SNAP and WIC v. only WIC benefits. Public Health Nutr. 2016 Sep 9:1–8. doi: 10.1017/s1368980016002329. PMID: 27609603.27609603
32 MacDonald JM, Stokes RJ, Cohen DA, . The effect of light rail transit on body mass index and physical activity. Am J Prev Med. 2010 Aug;39(2):105–12. doi: 10.1016/j.amepre.2010.03.016. PMID: 20621257.20621257
33 Madsen KA. School-based body mass index screening and parent notification: a statewide natural experiment. Arch Pediatr Adolesc Med. 2011 Nov;165(11):987–92. doi: 10.1001/archpediatrics.2011.127. PMID: 21727262.21727262
34 Malakellis M, Hoare E, Sanigorski A, . School-based systems change for obesity prevention in adolescents: outcomes of the Australian Capital Territory ‘It’s Your Move!’. Aust N Z J Public Health. 2017 Jul 27doi: 10.1111/1753-6405.12696. PMID: 28749562.28749562
35 Masse LC, de Niet-Fitzgerald JE, Watts AW, . Associations between the school food environment, student consumption and body mass index of Canadian adolescents. Int J Behav Nutr Phys Act. 2014 Mar 26;11(1):29. doi: 10.1186/1479-5868-11-29. PMID: 24666770.24666770
36 Miewald C, Holben D, Hall P. Role of a food box program in fruit and vegetable consumption and food security. Can J Diet Pract Res. 2012 Summer;73(2):59–65. doi: 10.3148/73.2.2012.59. PMID: 22668838.22668838
37 Miller HJ, Tribby CP, Brown BB, . Public transit generates new physical activity: Evidence from individual GPS and accelerometer data before and after light rail construction in a neighborhood of Salt Lake City, Utah, USA. Health Place. 2015 Nov;36:8–17. doi: 10.1016/j.healthplace.2015.08.005.26340643
38 Nanney MS, MacLehose RF, Kubik MY, . School Obesity Prevention Policies and Practices in Minnesota and Student Outcomes: A Longitudinal Cohort Study. Am J Prev Med. 2016 Nov;51(5):656–63. doi: 10.1016/j.amepre.2016.05.008. PMID: 27320703.27320703
39 Nguyen BT, Powell LM. Supplemental nutrition assistance program participation and sugar-sweetened beverage consumption, overall and by source. Prev Med. 2015 Dec;81:82–6. doi: 10.1016/j.ypmed.2015.08.003. PMID: 26303370.26303370
40 Olsho LE, Payne GH, Walker DK, . Impacts of a farmers’ market incentive programme on fruit and vegetable access, purchase and consumption. Public Health Nutr. 2015 Oct;18(15):2712–21. doi: 10.1017/s1368980015001056. PMID: 25919225.25919225
41 Parsons WG, Garcia GM, Hoffman PK. Evaluating school wellness policy in curbing childhood obesity in Anchorage, Alaska. J Sch Nurs. 2014 Oct;30(5):324–31. doi: 10.1177/1059840513513155. PMID: 24316497.24316497
42 Peterson KE, Spadano-Gasbarro JL, Greaney ML, . Three-Year Improvements in Weight Status and Weight-Related Behaviors in Middle School Students: The Healthy Choices Study. PLoS One. 2015;10(8):e0134470. doi: 10.1371/journal.pone.0134470. PMID: 26295837.26295837
43 Powell LM, Chriqui J, Chaloupka FJ. Associations between state-level soda taxes and adolescent body mass index. J Adolesc Health. 2009 Sep;45(3 Suppl):S57–63. doi: 10.1016/j.jadohealth.2009.03.003. PMID: 19699437.19699437
44 Quigg R, Reeder AI, Gray A, . The Effectiveness of a Community Playground Intervention. Journal of Urban Health-Bulletin of the New York Academy of Medicine. 2012 Feb;89(1):171–84. doi: 10.1007/s11524-011-9622-1.21959697
45 Restrepo BJ. Calorie Labeling in Chain Restaurants and Body Weight: Evidence from New York. Health Econ. 2016 Jul 24doi: 10.1002/hec.3389. PMID: 27451966.27451966
46 Riis J, Grason H, Strobino D, . State school policies and youth obesity. Matern Child Health J. 2012 Apr;16 Suppl 1:S111–8. doi: 10.1007/s10995-012-1000-4. PMID: 22527761.22527761
47 Robles B, Montes CE, Nobari TZ, . Dietary Behaviors among Public Health Center Clients with Electronic Benefit Transfer Access at Farmers’ Markets. J Acad Nutr Diet. 2017 Jan;117(1):58–68. doi: 10.1016/j.jand.2016.07.012. PMID: 27618576.27618576
48 Sabia JJ, Nguyen TT, Rosenberg O. High School Physical Education Requirements and Youth Body Weight: New Evidence from the YRBS. Health Econ. 2016 Aug 30doi: 10.1002/hec.3399. PMID: 27576770.27576770
49 Schwartz AE, Leardo M, Aneja S, . Effect of a School-Based Water Intervention on Child Body Mass Index and Obesity. JAMA Pediatr. 2016 Mar;170(3):220–6. doi: 10.1001/jamapediatrics.2015.3778. PMID: 26784336.26784336
50 Sekhobo JP, Edmunds LS, Dalenius K, . Neighborhood disparities in prevalence of childhood obesity among low-income children before and after implementation of New York City child care regulations. Prev Chronic Dis. 2014;11:E181. doi: 10.5888/pcd11.140152. PMID: 25321632.25321632
51 Sturm R, Powell LM, Chriqui JF, . Soda Taxes, Soft Drink Consumption, And Children’s Body Mass Index. Health Affairs. 2010 May–Jun;29(5):1052–8. doi: 10.1377/hlthaff.2009.0061.20360173
52 Sturm R, Hattori A. Diet and obesity in Los Angeles County 2007–2012: Is there a measurable effect of the 2008 “Fast-Food Ban”? Soc Sci Med. 2015 May;133:205–11. doi: 10.1016/j.socscimed.2015.03.004. PMID: 25779774.25779774
53 Taber DR, Stevens J, Evenson KR, . State policies targeting junk food in schools: racial/ethnic differences in the effect of policy change on soda consumption. Am J Public Health. 2011 Sep;101(9):1769–75. doi: 10.2105/ajph.2011.300221. PMID: 21778484.21778484
54 Taber DR, Chriqui JF, Perna FM, . Weight status among adolescents in States that govern competitive food nutrition content. Pediatrics. 2012 Sep;130(3):437–44. doi: 10.1542/peds.2011-3353. PMID: 22891223.22891223
55 Toussaint LL, Housholder K, Janssen K, . Slowing BMI Growth Trajectories in Elementary School-Aged Children: The Northeast Iowa Food and Fitness Initiative. Fam Community Health. 2017 Jul/Sep;40(3):192–7. doi: 10.1097/fch.0000000000000151. PMID: 28525438.28525438
56 Utter J, Denny S, Dyson B. School gardens and adolescent nutrition and BMI: Results from a national, multilevel study. Prev Med. 2016 Feb;83:1–4. doi: 10.1016/j.ypmed.2015.11.022. PMID: 26657347.26657347
57 von Hippel PT, Bradbury WK. The effects of school physical education grants on obesity, fitness, and academic achievement. Prev Med. 2015 Sep;78:44–51. doi: 10.1016/j.ypmed.2015.06.011. PMID: 26163396.26163396
58 Webb E, Netuveli G, Millett C. Free bus passes, use of public transport and obesity among older people in England. J Epidemiol Community Health. 2012 Feb;66(2):176–80. doi: 10.1136/jech.2011.133165. PMID: 21911850.21911850
59 Wells L, Nelson M. The National School Fruit Scheme produces short-term but not longer-term increases in fruit consumption in primary school children. Br J Nutr. 2005 Apr;93(4):537–42. PMID: 15946417.15946417
60 Woodward-Lopez G, Gosliner W, Samuels SE, . Lessons learned from evaluations of California’s statewide school nutrition standards. Am J Public Health. 2010 Nov;100(11):2137–45. doi: 10.2105/ajph.2010.193490. PMID: 20864696.20864696
61 Ludwig J, Sanbonmatsu L, Gennetian L, . Neighborhoods, obesity, and diabetes--a randomized social experiment. N Engl J Med. 2011 Oct 20;365(16):1509–19. doi: 10.1056/NEJMsa1103216. PMID: 22010917.22010917
62 Perry CL, Bishop DB, Taylor GL, . A randomized school trial of environmental strategies to encourage fruit and vegetable consumption among children. Health Educ Behav. 2004 Feb;31(1):65–76. PMID: 14768658.14768658
63 Naylor PJ, Macdonald HM, Zebedee JA, . Lessons learned from Action Schools! BC--an ‘active school’ model to promote physical activity in elementary schools. J Sci Med Sport. 2006 Oct;9(5):413–23. doi: 10.1016/j.jsams.2006.06.013. PMID: 16884957.16884957
64 Pope M. Preventing Weight Gain in Children Who Are School Age and African-American. Pediatr Phys Ther. 2016 Summer;28(2):207–16. doi: 10.1097/pep.0000000000000243. PMID: 26914717.26914717
65 Rush E, McLennan S, Obolonkin V, . Project Energize: whole-region primary school nutrition and physical activity programme; evaluation of body size and fitness 5 years after the randomised controlled trial. Br J Nutr. 2014 Jan 28;111(2):363–71. doi: 10.1017/s0007114513002316. PMID: 23867069.23867069
66 Lorentzen C, Ommundsen Y, Jenum AK, . The “Romsas in Motion” community intervention: mediating effects of psychosocial factors on forward transition in the stages of change in physical activity. Health Educ Behav. 2009 Apr;36(2):348–65. doi: 10.1177/1090198107308372. PMID: 18065570.18065570
67 Evans CE, Ransley JK, Christian MS, . A cluster-randomised controlled trial of a school-based fruit and vegetable intervention: Project Tomato. Public Health Nutr. 2013 Jun;16(6):1073–81. doi: 10.1017/s1368980012005290. PMID: 23237386.23237386
68 Cheadle A, Rauzon S, Spring R, . Kaiser Permanente ’s Community Health Initiative in Northern California: evaluation findings and lessons learned. Am J Health Promot. 2012 Nov–Dec;27(2):e59–68. doi: 10.4278/ajhp.111222-QUAN-462. PMID: 23113787.23113787
69 de Silva-Sanigorski A, Elea D, Bell C, . Obesity prevention in the family day care setting: impact of the Romp & Chomp intervention on opportunities for children’s physical activity and healthy eating. Child Care Health Dev. 2011 May;37(3):385–93. doi: 10.1111/j.1365-2214.2010.01205.x. PMID: 21276039.21276039