# Appendix I Programs, Policies, or Built Environment Changes in Included Studies (U.S. Only)

Table I1 Program, policy, or built environment evaluations in the United States at the government level (local, state/regional, or Federal)

2005 Safe Routes to School (SRTS) initiative^1^ | Healthy Foods, Healthy Families (HFHF)^2^ | Reach 2010^3^
Act 1220 (Arkansas): NMI screening^4^ | Healthy2Go: received training and technical assistance to increase availability and awareness of healthy foods^5^ | Ready for Recess^6^
AHOME^7^ | HEROES (Healthy, Energetic, Ready, Outstanding, Enthusiastic, Schools) Initiative^8^ | Reduced availability of sugar sweetened beverage and diet soda in a la carte and vending programs in Maine public high schools.^9^
All Sugar Sweetened Beverage Ban and the only soda ban^10^ | High 5^11^ | Regulations governing minimum PA standards in child care centers^12^
an independent grocery store (Witherbee’s Market) at the center of the Carriage Town neighborhood^13^ | HUD assignment for urban housing.^14^ | Residents moving to a new urbanist neighborhood^15^
Analysis of CLASS and NSCH^16^ | installation of new bicycle boulevards.^17^ | results of different school nutrition policies^18^
Anchorage School District’s School Wellness Policy^19^ | Instant Recess^20^ | Route H^21^
ATLAS^22^ | Joint Use Policies^23^ | School Breakfast Program (SBP) and National School Lunch program^24^
Bootheel Walking Promotion Project (creation of walking trails)^25^ | Kearney Public School (KPS) District; population dose study^26^ | School garden^27^
Boston Active School Day Policy^28^ | Kid’s Choice Program^29^ | School meals^30^
Boston Public Schools Snack and Beverage Policy^31^ | LA Sprouts: gardening, nutrition and cooking intervention^32^ | School Nutrition Policy Initiative (SNPI)^33^
Breakfast service policy^34^ | Learning Landscape^35^ | School-specific policies/program^36^
Bright Start^37^ | LEED for Neighborhood Development (LEED-ND)^38^ | Schoolwide food policies and practices^39^
Building new greenway^40^ | Let’s Go!^41^ | Senate Bill 12 (SB 12), California^42^
California Childhood Obesity Prevention Act: Obesity Prevention Motion; Obesity Prevention Motion^43^ | Light rail transit^44, 45^ | Senate Bill SB 677; Los Angeles Unified School District Nutrition Policy^46^
Calorie Labeling Laws in New York City jurisdictions^47^ | Los Angeles Fast Food ban^48^ | SNAP (Food stamp program)^49^
Calorie-labeling policy^50^ | Mean distance walked per day for transportation purposes^51^ | SPARK (Sports, Play and Active Recreation for Kids)^52^
Child Nutrition and WIC Reauthorization Act (CNRA)^53, 54^ | Mebane on the Move Intervention^55^ | Standing desks in classrooms^56^
Children’s Healthy Living Program for Remote Underserved Minority Populations in the Pacific Region (CHL)^57^ | Michigan Farmers’ Market Nutrition Program^58^ | State competitive food laws and state physical education laws ^59^
Colorado Trust^60^ | Michigan State Board of Education (MSBE) nutrition policy^61, 62^ | state high school physical education requirements^63^
Communities Putting Prevention to Work (CPPW)^64^ | Middle-School Physical Activity and Nutrition (M-SPAN)^65^ | State laws regarding the nutrition content of competitive foods sold in high schools^66^
Community Health Advisor^67^ | Mississippi Fresh Fruit and Vegetable Program (MFVP)^68^ | State Soda Tax^69^
Community Interventions for Health: build walking trails, bike service system^70^ | mixed-use redevelopment community in metropolitan Atlanta (Atlantic Station) that promotes walking and physical activity^71^ | State-level grocery story and vending machine soda taxes^72^
Community-Supported Agriculture (CSA)^73^ | Moving Across Places^74, 75^ | Step Ahead trial^76^
Competitive Food Laws (varies by state) in 40 States^77^ | Moving to a walkable community^78^ | Supplemental Nutrition Assistance Program (SNAP)^79–83^
Competitive foods and beverages policies in public schools in multple states: NY, WA, NC, GA, TX, KY, TN, LA, GA, OK, KS^84^ | Multilevel community intervention^85^ | Texas Fitness Now (TFN)^86^
Complete streets design^87^ | Multi-level intervention to influence children’s’ PA behaviors^88^ | Texas Public School Nutrition Policy^89^
Comprehensive School Physical Activity Program (CSPAP)^90^ | Multiple state laws for 50 states and DC^91^ | Texas Senate Bill 42 (SB42)^92^
Comprehensive school-based intervention on healthy behavior^93^ | Munch and Move^94^ | The Active Early program^95^
Coordinated School Health Program (CSHP)^96^ | National School Lunch Program^97, 98^ | The COMMUNICATE (COMMUNIty-wide Campaign To promote Exercise)^99^
Electronic Benefit Transfer (EBT) at farmers markets^100^ | Navajo Healthy Stores (NHS) program^101^ | The HEALTHY Intervention^102^
Energize Your Life!^103^ | New urbanist neighborhood (in comparison to traditional suburban neighborhood)^104^ | The Healthy Youth Places^105^
Environmental Modifications (EMs)^106^ | New York City’s Food Retail Expansion to Support Health (FRESH)^107^ | The Learning, Cognition & Motion (LCoMotion) study^108^
Excise tax on SSB^109^ | North Carolina Health and Wellness Trust Fund (NCHWTF)^110^ | The Mālaekahana Bike Path^111^
Fitness Zone^112^ | Opening access to schoolyard outside of regular operation hours^113^ | The Northwest Iowa Food and Fitness Initiative: Regional Safe Routes to School Programming (see www.saferoutestoschools.org), Walking School Buses, and bike rodeos ^114^
Food Dudes^115^ | Partnerships for Active Children in Elementary Schools (PACES)^116^ | The School Obesity-related Policy Evaluation study (ScOPE)^117^
Fresh fruit availability at worksites^118^ | Pathways Program (food protion focused on providing lower fat foods)^119^ | The Supplemental Nutrition Assistance Program (SNAP)^120^
Fresh to You Markets^121^ | Pennsylvania Fresh Food Financing Initiative^122^ | Vacant lot greening program^123^
Fruit and vegetable promotion in stores with staff training and installing new equipment^124^ | Physical Activity and Healthy Food Intervention^125^ | Walking school Bus^126^
Go!^127^ | Physical education state policies^128^ | Wheeling Walks^129, 130^
Gold Medal Schools program^131^ | playground upgrade program^132^ | WIC^133, 134^
Head Start: classroom videotaped (DVD) puppet shows.^135^ | Policy Changes Targeting Junk Food in School vending machines^136^ | WIC and SNAP^137^
Health Bucks: Farmers’ market incentive program^138^ | Pro Children^139^ | Workplace showers^140^
Healthier Missouri Communities^141^ | Project CHOICE (Center for Healthy Options and Community Empowerment)- community-based participatory research study^142^ | YRBSS merged with state policies^143, 144^
Healthier nutrition guidelines^145^ | Project Healthy Schools^146^
Healthy Choice^147^ | Proyecto Mercado FRESCO^148^
Healthy Communities Study (HCS)^149^ | Railroad Park^150^

Table I2 Program, policy, or built environment evaluations in the United States at the nongovernment level

Men on the Move: Growing Communities (MOTMGC)^151^ | Movin’ Afterschool^152^ | Lifestyle Education for Activity Program^153^
Lookin’ Good Feelin’ Good: School nurse intervention and after-school exercise program^154^ | Healthy Eating Active Living–Community Health Initiative (HEAL-CHI)^155^ | Healthy Schools Program (HSP)^156^
Project Healthy Schools in two Cities in Michigan^157^ | Kids N Fitness^158^ | Choosing Healthy & Active Lifestyles for Kids (CHALK)^159^
Physical Activity 4 Everyone^160^ | Sports, Play, and Active Recreation for Kids (SPARK)^161^ | Positive Action for Today’s Health^162^
Healthy Food Financing Initiative^163^ | The Healthy Options for Nutrition Environments in Schools (Healthy ONES)^164^ | New Moves intervention^165^
APPLE^166^ | HealthWorks^167^ | ‘Intervention Centered on Adolescents’ Physical activity and Sedentary behavior’ (ICAPS)^168^
Energy Balance for Kids with Play (EB4K with Play)^169^ | Partnership for an Active Community Environment (PACE) and city of New Orleans^170^ | America SCORES^171^
Healthy Store Intervention^172^ | Water Jet installation in schools^173^ | The Cafeteria Power Plus Intervention^174^
Physical activity intervention^175^ | The Healthy Foods Hawaii (HFH)^176^ | Creating Healthy, Active and Nurturing Growing-up Environments (CHANGE) study: serve healthier school breakfast and lunch^177^
The HealthMPowers program^178^ | Healthy Living Cambridge Kids (KLCK)^179^ | The 5 a Day intervention: newsletters and promotions to encourage healthy eating^180^
Multi-level weight-gain prevention^181^ | Shape-Up Somerville^182^ | Health promotion messaging and counseling ^183^
Romp & Chomp^184^ | JUMP-in^185^ | A social marketing intervention promoted walking^186^

## References for Appendix I

1 Hoelscher D, Ory M, Dowdy D, . Effects of funding allocation for Safe Routes to School programs on active commuting to school and related behavioral, knowledge, and psychosocial outcomes: Results from the Texas Childhood Obesity Prevention Policy Evaluation (T-COPPE) study. Environ Behav. 2016;48(1):210–29. doi: 10.1177/0013916515613541. PMID: 2016-02263-012.
2 Bowling AB, Moretti M, Ringelheim K, . Healthy Foods, Healthy Families: combining incentives and exposure interventions at urban farmers’ markets to improve nutrition among recipients of US federal food assistance. Health Promot Perspect. 2016;6(1):10–6. doi: 10.15171/hpp.2016.02. PMID: 27123431.27123431
3 Liao Y, Siegel PZ, Zhou H, . Reduced Disparity in Vegetable Consumption in 16 Disadvantaged Black Communities: A Successful 5-Year Community-Based Participatory Intervention. J Racial Ethn Health Disparities. 2015 Jun;2(2):211–8. doi: 10.1007/s40615-014-0065-8. PMID: 26150921.26150921
4 Gee KA. School-Based Body Mass Index Screening and Parental Notification in Late Adolescence: Evidence From Arkansas’s Act 1220. J Adolesc Health. 2015 Sep;57(3):270–6. doi: 10.1016/j.jadohealth.2015.05.007. PMID: 26115907.26115907
5 Rushakoff JA, Zoughbie DE, Bui N, . Evaluation of Healthy2Go: A country store transformation project to improve the food environment and consumer choices in Appalachian Kentucky. Prev Med Rep. 2017 Sep;7:187–92. doi: 10.1016/j.pmedr.2017.06.009. PMID: 28706778.28706778
6 Huberty JL, Beets MW, Beighle A, . Environmental modifications to increase physical activity during recess: preliminary findings from ready for recess. J Phys Act Health. 2011 Sep;8 Suppl 2:S249–56. PMID: 21918239.21918239
7 Camacho-Rivera M, Rosenbaum E, Yama C, . Low-Income Housing Rental Assistance, Perceptions of Neighborhood Food Environment, and Dietary Patterns among Latino Adults: the AHOME Study. J Racial Ethn Health Disparities. 2017 Jun;4(3):346–53. doi: 10.1007/s40615-016-0234-z. PMID: 27129854.27129854
8 King MH, Lederer AM, Sovinski D, . Implementation and evaluation of the HEROES initiative: a tri-state coordinated school health program to reduce childhood obesity. Health Promot Pract. 2014 May;15(3):395–405. doi: 10.1177/1524839913512835. PMID: 24334542.24334542
9 Blum JE, Davee AM, Beaudoin CM, . Reduced availability of sugar-sweetened beverages and diet soda has a limited impact on beverage consumption patterns in Maine high school youth. J Nutr Educ Behav. 2008 Nov–Dec;40(6):341–7. doi: 10.1016/j.jneb.2007.12.004. PMID: 18984489.18984489
10 Taber DR, Chriqui JF, Powell LM, . Banning all sugar-sweetened beverages in middle schools: reduction of in-school access and purchasing but not overall consumption. Arch Pediatr Adolesc Med. 2012 Mar;166(3):256–62. doi: 10.1001/archpediatrics.2011.200. PMID: 22064875.22064875
11 Reynolds KD, Franklin FA, Binkley D, . Increasing the fruit and vegetable consumption of fourth-graders: results from the high 5 project. Prev Med. 2000 Apr;30(4):309–19. doi: 10.1006/pmed.1999.0630. PMID: 10731460.10731460
12 Stephens RL, Xu Y, Lesesne CA, . Relationship between child care centers’ compliance with physical activity regulations and children’s physical activity, New York City, 2010. Prev Chronic Dis. 2014 Oct 16;11:E179. doi: 10.5888/pcd11.130432. PMID: 25321630.25321630
13 Sadler RC, Gilliland JA, Arku G. A food retail-based intervention on food security and consumption. Int J Environ Res Public Health. 2013 Aug 05;10(8):3325–46. doi: 10.3390/ijerph10083325. PMID: 23921626.23921626
14 Ludwig J, Sanbonmatsu L, Gennetian L, . Neighborhoods, obesity, and diabetes--a randomized social experiment. N Engl J Med. 2011 Oct 20;365(16):1509–19. doi: 10.1056/NEJMsa1103216. PMID: 22010917.22010917
15 Calise TV, Heeren T, DeJong W, . Do neighborhoods make people active, or do people make active neighborhoods? Evidence from a planned community in Austin, Texas. Prev Chronic Dis. 2013 Jun 20;10:E102. doi: 10.5888/pcd10.120119. PMID: 23786909.23786909
16 Oh AY, Hennessy E, McSpadden KE, . Contextual Influences on Weight Status Among Impoverished Adolescents: Neighborhood Amenities for Physical Activity and State Laws for Physical Education Time Requirements. J Phys Act Health. 2015 Jun;12(6):875–8. doi: 10.1123/jpah.2013-0303. PMID: 25109235.25109235
17 Dill J, McNeil N, Broach J, . Bicycle boulevards and changes in physical activity and active transportation: findings from a natural experiment. Prev Med. 2014 Dec;69 Suppl 1:S74–8. doi: 10.1016/j.ypmed.2014.10.006. PMID: 25456802.25456802
18 Riis J, Grason H, Strobino D, . State school policies and youth obesity. Matern Child Health J. 2012 Apr;16 Suppl 1:S111–8. doi: 10.1007/s10995-012-1000-4. PMID: 22527761.22527761
19 Parsons WG, Garcia GM, Hoffman PK. Evaluating school wellness policy in curbing childhood obesity in Anchorage, Alaska. J Sch Nurs. 2014 Oct;30(5):324–31. doi: 10.1177/1059840513513155. PMID: 24316497.24316497
20 Whitt-Glover MC, Ham SA, Yancey AK. Instant Recess(R): a practical tool for increasing physical activity during the school day. Prog Community Health Partnersh. 2011 Fall;5(3):289–97. doi: 10.1353/cpr.2011.0031. PMID: 22080777.22080777
21 French SA, Harnack LJ, Hannan PJ, . Worksite environment intervention to prevent obesity among metropolitan transit workers. Prev Med. 2010 Apr;50(4):180–5. doi: 10.1016/j.ypmed.2010.01.002. PMID: 20079369.20079369
22 Lubans DR, Smith JJ, Plotnikoff RC, . Assessing the sustained impact of a school-based obesity prevention program for adolescent boys: the ATLAS cluster randomized controlled trial. Int J Behav Nutr Phys Act. 2016 Aug 20;13:92. doi: 10.1186/s12966-016-0420-8. PMID: 27542825.27542825
23 Slater S, Chriqui J, Chaloupka FJ, . Joint use policies: are they related to adolescent behavior? Prev Med. 2014 Dec;69 Suppl 1:S37–43. doi: 10.1016/j.ypmed.2014.08.032. PMID: 25199731.25199731
24 Capogrossi K, You W. The Influence of School Nutrition Programs on the Weight of Low-Income Children: A Treatment Effect Analysis. Health Econ. 2016 Jul 6doi: 10.1002/hec.3378. PMID: 27381591.27381591
25 Brownson RC, Baker EA, Boyd RL, . A community-based approach to promoting walking in rural areas. Am J Prev Med. 2004 Jul;27(1):28–34. doi: 10.1016/j.amepre.2004.03.015. PMID: 15212772.15212772
26 Heelan KA, Bartee RT, Nihiser A, . Healthier School Environment Leads to Decreases in Childhood Obesity: The Kearney Nebraska Story. Child Obes. 2015 Oct;11(5):600–7. doi: 10.1089/chi.2015.0005. PMID: 26440386.26440386
27 Wells NM, Myers BM, Henderson CR, Jr. School gardens and physical activity: a randomized controlled trial of low-income elementary schools. Prev Med. 2014 Dec;69 Suppl 1:S27–33. doi: 10.1016/j.ypmed.2014.10.012. PMID: 25456803.25456803
28 Cradock AL, Barrett JL, Carter J, . Impact of the Boston Active School Day policy to promote physical activity among children. Am J Health Promot. 2014 Jan–Feb;28(3 Suppl):S54–64. doi: 10.4278/ajhp.130430-QUAN-204. PMID: 24380467.24380467
29 Hendy HM, Williams KE, Camise TS. Kid’s Choice Program improves weight management behaviors and weight status in school children. Appetite. 2011 Apr;56(2):484–94. doi: 10.1016/j.appet.2011.01.024. PMID: 21277924.21277924
30 Gleason PM, Dodd AH. School Breakfast Program but Not School Lunch Program Participation Is Associated with Lower Body Mass Index. J Am Diet Assoc. 2009 Feb;109(2):S118–S28. doi: 10.1016/j.jada.2008.10.058. PMID: 19166666.19166666
31 Cradock AL, McHugh A, Mont-Ferguson H, . Effect of school district policy change on consumption of sugar-sweetened beverages among high school students, Boston, Massachusetts, 2004–2006. Prev Chronic Dis. 2011 Jul;8(4):A74. PMID: 21672398.21672398
32 Gatto NM, Martinez LC, Spruijt-Metz D, . LA sprouts randomized controlled nutrition, cooking and gardening programme reduces obesity and metabolic risk in Hispanic/Latino youth. Pediatr Obes. 2017 Feb;12(1):28–37. doi: 10.1111/ijpo.12102. PMID: 26909882.26909882
33 Foster GD, Sherman S, Borradaile KE, . A policy-based school intervention to prevent overweight and obesity. Pediatrics. 2008 Apr;121(4):e794–802. doi: 10.1542/peds.2007-1365. PMID: 18381508.18381508
34 Ritchie LD, Rosen NJ, Fenton K, . School Breakfast Policy Is Associated with Dietary Intake of Fourth- and Fifth-Grade Students. J Acad Nutr Diet. 2016 Mar;116(3):449–57. doi: 10.1016/j.jand.2015.08.020. PMID: 26433452.26433452
35 Anthamatten P, Brink L, Lampe S, . An assessment of schoolyard renovation strategies to encourage children’s physical activity. Int J Behav Nutr Phys Act. 2011 Apr 09;8:27. doi: 10.1186/1479-5868-8-27. PMID: 21477325.21477325
36 Nanney MS, MacLehose RF, Kubik MY, . School Obesity Prevention Policies and Practices in Minnesota and Student Outcomes: A Longitudinal Cohort Study. Am J Prev Med. 2016 Nov;51(5):656–63. doi: 10.1016/j.amepre.2016.05.008. PMID: 27320703.27320703
37 Story M, Hannan PJ, Fulkerson JA, . Bright Start: Description and main outcomes from a group-randomized obesity prevention trial in American Indian children. Obesity (Silver Spring). 2012 Nov;20(11):2241–9. doi: 10.1038/oby.2012.89. PMID: 22513491.22513491
38 Zhu X, Lu Z, Yu C, . Walkable communities: impacts on residents’ physical and social health. World Health Des 2013;7:68–75.
39 Kubik MY, Lytle LA, Story M. Schoolwide food practices are associated with body mass index in middle school students. Arch Pediatr Adolesc Med. 2005 Dec;159(12):1111–4. doi: 10.1001/archpedi.159.12.1111. PMID: 16330732.16330732
40 West ST, Shores KA. The impacts of building a greenway on proximate residents’ physical activity. J Phys Act Health. 2011 Nov;8(8):1092–7. PMID: 22039127.22039127
41 Madsen KA. School-based body mass index screening and parent notification: a statewide natural experiment. Arch Pediatr Adolesc Med. 2011 Nov;165(11):987–92. doi: 10.1001/archpediatrics.2011.127. PMID: 21727262.21727262
42 Woodward-Lopez G, Gosliner W, Samuels SE, . Lessons learned from evaluations of California’s statewide school nutrition standards. Am J Public Health. 2010 Nov;100(11):2137–45. doi: 10.2105/ajph.2010.193490. PMID: 20864696.20864696
43 Sanchez-Vaznaugh EV, Sanchez BN, Baek J, . ‘Competitive’ food and beverage policies: are they influencing childhood overweight trends? Health Aff (Millwood). 2010 Mar–Apr;29(3):436–46. doi: 10.1377/hlthaff.2009.0745. PMID: 20194985.20194985
44 Miller HJ, Tribby CP, Brown BB, . Public transit generates new physical activity: Evidence from individual GPS and accelerometer data before and after light rail construction in a neighborhood of Salt Lake City, Utah, USA. Health Place. 2015 Nov;36:8–17. doi: 10.1016/j.healthplace.2015.08.005.26340643
45 MacDonald JM, Stokes RJ, Cohen DA, . The effect of light rail transit on body mass index and physical activity. Am J Prev Med. 2010 Aug;39(2):105–12. doi: 10.1016/j.amepre.2010.03.016. PMID: 20621257.20621257
46 Bauhoff S. The effect of school district nutrition policies on dietary intake and overweight: a synthetic control approach. Econ Hum Biol. 2014 Jan;12:45–55. doi: 10.1016/j.ehb.2013.06.001. PMID: 23891422.23891422
47 Restrepo BJ. Calorie Labeling in Chain Restaurants and Body Weight: Evidence from New York. Health Econ. 2016 Jul 24doi: 10.1002/hec.3389. PMID: 27451966.27451966
48 Sturm R, Hattori A. Diet and obesity in Los Angeles County 2007–2012: Is there a measurable effect of the 2008 “Fast-Food Ban”? Soc Sci Med. 2015 May;133:205–11. doi: 10.1016/j.socscimed.2015.03.004. PMID: 25779774.25779774
49 Howlett E, Davis C, Burton S. From food desert to food oasis: The potential influence of food retailers on childhood obesity rates. Journal of Business Ethics. 2016;139(2):215–24. doi: 10.1007/s10551-015-2605-5. PMID: 2015-12722-001.
50 Vadiveloo MK, Dixon LB, Elbel B. Consumer purchasing patterns in response to calorie labeling legislation in New York City. Int J Behav Nutr Phys Act. 2011 May 27;8:51. doi: 10.1186/1479-5868-8-51. PMID: 21619632.21619632
51 Lachapelle U, Frank LD. Transit and health: mode of transport, employer-sponsored public transit pass programs, and physical activity. J Public Health Policy. 2009;30 Suppl 1:S73–94. doi: 10.1057/jphp.2008.52. PMID: 19190584.19190584
52 Fu Y, Gao Z, Hannon JC, . Effect of the SPARK Program on Physical Activity, Cardiorespiratory Endurance, and Motivation in Middle-School Students. J Phys Act Health. 2016 May;13(5):534–42. doi: 10.1123/jpah.2015-0351. PMID: 26528889.26528889
53 Coffield JE, Metos JM, Utz RL, . A multivariate analysis of federally mandated school wellness policies on adolescent obesity. J Adolesc Health. 2011 Oct;49(4):363–70. doi: 10.1016/j.jadohealth.2011.01.010. PMID: 21939866.21939866
54 Anderson LM, Aycock KE, Mihalic CA, . Geographic differences in physical education and adolescent BMI: have legal mandates made a difference? J Sch Nurs. 2013 Feb;29(1):52–60. doi: 10.1177/1059840512453602. PMID: 22815346.22815346
55 Benjamin Neelon SE, Namenek Brouwer RJ, Ostbye T, . A community-based intervention increases physical activity and reduces obesity in school-age children in North Carolina. Child Obes. 2015 Jun;11(3):297–303. doi: 10.1089/chi.2014.0130. PMID: 25938983.25938983
56 Wendel ML, Benden ME, Zhao H, . Stand-Biased Versus Seated Classrooms and Childhood Obesity: A Randomized Experiment in Texas. Am J Public Health. 2016 Oct;106(10):1849–54. doi: 10.2105/ajph.2016.303323. PMID: 27552276.27552276
57 Esquivel M, Nigg CR, Fialkowski MK, . Head Start Wellness Policy Intervention in Hawaii: A Project of the Children’s Healthy Living Program. Child Obes. 2016 Feb;12(1):26–32. doi: 10.1089/chi.2015.0071. PMID: 26771119.26771119
58 Anderson JV, Bybee DI, Brown RM, . 5 a day fruit and vegetable intervention improves consumption in a low income population. J Am Diet Assoc. 2001 Feb;101(2):195–202. doi: 10.1016/s0002-8223(01)00052-9. PMID: 11271692.11271692
59 Taber DR, Chriqui JF, Perna FM, . Association between state physical education (PE) requirements and PE participation, physical activity, and body mass index change. Prev Med. 2013 Nov;57(5):629–33. doi: 10.1016/j.ypmed.2013.08.018. PMID: 23978523.23978523
60 Caldwell EM, Miller Kobayashi M, DuBow WM, . Perceived access to fruits and vegetables associated with increased consumption. Public Health Nutr. 2009 Oct;12(10):1743–50. doi: 10.1017/s1368980008004308. PMID: 19105861.19105861
61 Schwartz AE, Leardo M, Aneja S, . Effect of a School-Based Water Intervention on Child Body Mass Index and Obesity. JAMA Pediatr. 2016 Mar;170(3):220–6. doi: 10.1001/jamapediatrics.2015.3778. PMID: 26784336.26784336
62 Alaimo K, Oleksyk SC, Drzal NB, . Effects of changes in lunch-time competitive foods, nutrition practices, and nutrition policies on low-income middle-school children’s diets. Child Obes. 2013 Dec;9(6):509–23. doi: 10.1089/chi.2013.0052. PMID: 24215386.24215386
63 Sabia JJ, Nguyen TT, Rosenberg O. High School Physical Education Requirements and Youth Body Weight: New Evidence from the YRBS. Health Econ. 2016 Aug 30doi: 10.1002/hec.3399. PMID: 27576770.27576770
64 Kern E, Chan NL, Fleming DW, . Declines in student obesity prevalence associated with a prevention initiative - King County, Washington, 2012. MMWR Morb Mortal Wkly Rep. 2014 Feb 21;63(7):155–7. PMID: 24553199.24553199
65 Sallis JF, McKenzie TL, Conway TL, . Environmental interventions for eating and physical activity: a randomized controlled trial in middle schools. Am J Prev Med. 2003 Apr;24(3):209–17. PMID: 12657338.12657338
66 Taber DR, Chriqui JF, Chaloupka FJ. Differences in nutrient intake associated with state laws regarding fat, sugar, and caloric content of competitive foods. Arch Pediatr Adolesc Med. 2012 May;166(5):452–8. doi: 10.1001/archpediatrics.2011.1839. PMID: 22566546.22566546
67 Crespo NC, Elder JP, Ayala GX, . Results of a multi-level intervention to prevent and control childhood obesity among Latino children: the Aventuras Para Ninos Study. Ann Behav Med. 2012 Feb;43(1):84–100. doi: 10.1007/s12160-011-9332-7. PMID: 22215470.22215470
68 Coyle KK, Potter S, Schneider D, . Distributing free fresh fruit and vegetables at school: results of a pilot outcome evaluation. Public Health Rep. 2009 Sep–Oct;124(5):660–9. doi: 10.1177/003335490912400508. PMID: 19753944.19753944
69 Sturm R, Powell LM, Chriqui JF, . Soda Taxes, Soft Drink Consumption, And Children’s Body Mass Index. Health Affairs. 2010 May–Jun;29(5):1052–8. doi: 10.1377/hlthaff.2009.0061.20360173
70 Lv J, Liu QM, Ren YJ, . A community-based multilevel intervention for smoking, physical activity and diet: short-term findings from the Community Interventions for Health programme in Hangzhou, China. J Epidemiol Community Health. 2014 Apr;68(4):333–9. doi: 10.1136/jech-2013-203356. PMID: 24297972.24297972
71 Mumford KG, Contant CK, Weissman J, . Changes in physical activity and travel behaviors in residents of a mixed-use development. Am J Prev Med. 2011 Nov;41(5):504–7. doi: 10.1016/j.amepre.2011.07.016. PMID: 22011422.22011422
72 Powell LM, Chriqui J, Chaloupka FJ. Associations between state-level soda taxes and adolescent body mass index. J Adolesc Health. 2009 Sep;45(3 Suppl):S57–63. doi: 10.1016/j.jadohealth.2009.03.003. PMID: 19699437.19699437
73 Vasquez A, Sherwood NE, Larson N, . A novel dietary improvement strategy: examining the potential impact of community-supported agriculture membership. Public Health Nutr. 2016 Oct;19(14):2618–28. doi: 10.1017/s1368980015003638. PMID: 26857484.26857484
74 Brown BB, Smith KR, Tharp D, . A Complete Street Intervention for Walking to Transit, Nontransit Walking, and Bicycling: A Quasi-Experimental Demonstration of Increased Use. J Phys Act Health. 2016 Nov;13(11):1210–9. doi: 10.1123/jpah.2016-0066. PMID: 27334024.27334024
75 Brown BB, Werner CM, Tribby CP, . Transit Use, Physical Activity, and Body Mass Index Changes: Objective Measures Associated With Complete Street Light-Rail Construction. Am J Public Health. 2015 Jul;105(7):1468–74. doi: 10.2105/ajph.2015.302561. PMID: 25973829.25973829
76 Lemon SC, Zapka J, Li W, . Step ahead a worksite obesity prevention trial among hospital employees. Am J Prev Med. 2010 Jan;38(1):27–38. doi: 10.1016/j.amepre.2009.08.028. PMID: 20117554.20117554
77 Wright K, Norris K, Newman Giger J, . Improving healthy dietary behaviors, nutrition knowledge, and self-efficacy among underserved school children with parent and community involvement. Child Obes. 2012 Aug;8(4):347–56. doi: 10.1089/chi.2012.0045. PMID: 22867074.22867074
78 Zhu X, Yu CY, Lee C, . A retrospective study on changes in residents’ physical activities, social interactions, and neighborhood cohesion after moving to a walkable community. Prev Med. 2014 Dec;69 Suppl 1:S93–7. doi: 10.1016/j.ypmed.2014.08.013. PMID: 25158208.25158208
79 Nguyen BT, Powell LM. Supplemental nutrition assistance program participation and sugar-sweetened beverage consumption, overall and by source. Prev Med. 2015 Dec;81:82–6. doi: 10.1016/j.ypmed.2015.08.003. PMID: 26303370.26303370
80 Gibson D. Long-term Food Stamp Program participation is positively related to simultaneous overweight in young daughters and obesity in mothers. J Nutr. 2006 Apr;136(4):1081–5. PMID: 16549483.16549483
81 Molitor F, Sugerman S, Yu H, . Reach of Supplemental Nutrition Assistance Program-Education (SNAP-Ed) interventions and nutrition and physical activity-related outcomes, California, 2011–2012. Prev Chronic Dis. 2015 Mar 12;12:E33. doi: 10.5888/pcd12.140449. PMID: 25764139.25764139
82 Girard O, Brocherie F, Morin JB, . Intrasession and Intersession Reliability of Running Mechanics During Treadmill Sprints. Int J Sports Physiol Perform. 2016 May;11(4):432–9. doi: 10.1123/ijspp.2015-0145. PMID: 26356384.26356384
83 Leung CW, Blumenthal SJ, Hoffnagle EE, . Associations of food stamp participation with dietary quality and obesity in children. Pediatrics. 2013 Mar;131(3):463–72. doi: 10.1542/peds.2012-0889. PMID: 23439902.23439902
84 Datar A, Nicosia N. The effect of state competitive food and beverage regulations on childhood overweight and obesity. Journal of Adolescent Health. 2016doi: 10.1016/j.jadohealth.2016.09.003. PMID: 2016-54655-001.
85 Brownson RC, Hagood L, Lovegreen SL, . A multilevel ecological approach to promoting walking in rural communities. Prev Med. 2005 Nov–Dec;41(5–6):837–42. doi: 10.1016/j.ypmed.2005.09.004. PMID: 16256183.16256183
86 von Hippel PT, Bradbury WK. The effects of school physical education grants on obesity, fitness, and academic achievement. Prev Med. 2015 Sep;78:44–51. doi: 10.1016/j.ypmed.2015.06.011. PMID: 26163396.26163396
87 Brown BB, Werner CM, Smith KR, . Environmental, behavioral, and psychological predictors of transit ridership: Evidence from a community intervention. J Environ Psychol. 2016 Jun;46:188–96. doi: 10.1016/j.jenvp.2016.04.010. PMID: 27672237.27672237
88 Finch M, Wolfenden L, Morgan PJ, . A cluster randomized trial of a multi-level intervention, delivered by service staff, to increase physical activity of children attending center-based childcare. Prev Med. 2014 Jan;58:9–16. doi: 10.1016/j.ypmed.2013.10.004. PMID: 24145204.24145204
89 Cullen KW, Watson K, Zakeri I. Improvements in middle school student dietary intake after implementation of the Texas Public School Nutrition Policy. Am J Public Health. 2008 Jan;98(1):111–7. doi: 10.2105/ajph.2007.111765. PMID: 18048778.18048778
90 Brusseau TA, Hannon J, Burns R. The Effect of a Comprehensive School Physical Activity Program on Physical Activity and Health-Related Fitness in Children From Low-Income Families. J Phys Act Health. 2016 Aug;13(8):888–94. doi: 10.1123/jpah.2016-0028. PMID: 27144329.27144329
91 Hennessy E, Oh A, Agurs-Collins T, . State-level school competitive food and beverage laws are associated with children’s weight status. J Sch Health. 2014 Sep;84(9):609–16. doi: 10.1111/josh.12181. PMID: 25117896.25117896
92 Barroso CS, Kelder SH, Springer AE, . Senate Bill 42: implementation and impact on physical activity in middle schools. J Adolesc Health. 2009 Sep;45(3 Suppl):S82–90. doi: 10.1016/j.jadohealth.2009.06.017. PMID: 19699442.19699442
93 Ling J, King KM, Speck BJ, . Preliminary assessment of a school-based healthy lifestyle intervention among rural elementary school children. J Sch Health. 2014 Apr;84(4):247–55. doi: 10.1111/josh.12143. PMID: 24617908.24617908
94 Hardy LL, King L, Kelly B, . Munch and Move: evaluation of a preschool healthy eating and movement skill program. Int J Behav Nutr Phys Act. 2010 Nov 03;7:80. doi: 10.1186/1479-5868-7-80. PMID: 21047434.21047434
95 LaRowe TL, Tomayko EJ, Meinen AM, . Active Early: one-year policy intervention to increase physical activity among early care and education programs in Wisconsin. BMC Public Health. 2016 Jul 20;16:607. doi: 10.1186/s12889-016-3198-3. PMID: 27439770.27439770
96 Maddock J, Takeuchi L, Nett B, . Evaluation of a statewide program to reduce chronic disease: The Healthy Hawaii Initiative, 2000–2004. Eval Program Plann. 2006;29(3):293–300. doi: 10.1016/j.evalprogplan.2005.12.007. PMID: 2006-11996-009.
97 Fox MK, Dodd AH, Wilson A, . Association between school food environment and practices and body mass index of US public school children. J Am Diet Assoc. 2009 Feb;109(2 Suppl):S108–17. doi: 10.1016/j.jada.2008.10.065. PMID: 19166665.19166665
98 Schanzenbach D. Do School Lunches Contribute to Childhood Obesity?: Harris School of Public Policy Studies, University of Chicago, Working Papers: 0513; 2005.
99 Kamada M, Kitayuguchi J, Inoue S, . A community-wide campaign to promote physical activity in middle-aged and elderly people: a cluster randomized controlled trial. Int J Behav Nutr Phys Act. 2013 Apr 09;10:44. doi: 10.1186/1479-5868-10-44. PMID: 23570536.23570536
100 Robles B, Montes CE, Nobari TZ, . Dietary Behaviors among Public Health Center Clients with Electronic Benefit Transfer Access at Farmers’ Markets. J Acad Nutr Diet. 2017 Jan;117(1):58–68. doi: 10.1016/j.jand.2016.07.012. PMID: 27618576.27618576
101 Gittelsohn J, Kim EM, He S, . A food store-based environmental intervention is associated with reduced BMI and improved psychosocial factors and food-related behaviors on the Navajo nation. J Nutr. 2013 Sep;143(9):1494–500. doi: 10.3945/jn.112.165266. PMID: 23864511.23864511
102 Jago R, McMurray RG, Drews KL, . HEALTHY intervention: fitness, physical activity, and metabolic syndrome results. Med Sci Sports Exerc. 2011 Aug;43(8):1513–22. doi: 10.1249/MSS.0b013e31820c9797. PMID: 21233778.21233778
103 Shive SE, Morris MN. Evaluation of the energize your life! Social marketing campaign pilot study to increase fruit intake among community college students. J Am Coll Health. 2006 Jul–Aug;55(1):33–9. doi: 10.3200/jach.55.1.33-40. PMID: 16889313.16889313
104 Brown AL, Khattak AJ, Rodriguez DA. Neighbourhood Types, Travel and Body Mass: A Study of New Urbanist and Suburban Neighbourhoods in the US. Urban Stud. 2008;45(4):963–88.
105 Dzewaltowski DA, Estabrooks PA, Welk G, . Healthy youth places: a randomized controlled trial to determine the effectiveness of facilitating adult and youth leaders to promote physical activity and fruit and vegetable consumption in middle schools. Health Educ Behav. 2009 Jun;36(3):583–600. doi: 10.1177/1090198108314619. PMID: 18469366.18469366
106 Williamson DA, Champagne CM, Harsha DW, . Effect of an environmental school-based obesity prevention program on changes in body fat and body weight: a randomized trial. Obesity (Silver Spring). 2012 Aug;20(8):1653–61. doi: 10.1038/oby.2012.60. PMID: 22402733.22402733
107 Elbel B, Moran A, Dixon LB, . Assessment of a government-subsidized supermarket in a high-need area on household food availability and children’s dietary intakes. Public Health Nutr. 2015 Oct;18(15):2881–90. doi: 10.1017/s1368980015000282. PMID: 25714993.25714993
108 Tarp J, Domazet SL, Froberg K, . Effectiveness of a School-Based Physical Activity Intervention on Cognitive Performance in Danish Adolescents: LCoMotion-Learning, Cognition and Motion - A Cluster Randomized Controlled Trial. PLoS One. 2016;11(6):e0158087. doi: 10.1371/journal.pone.0158087. PMID: 27341346.27341346
109 Falbe J, Thompson HR, Becker CM, . Impact of the Berkeley Excise Tax on Sugar-Sweetened Beverage Consumption. Am J Public Health. 2016 Oct;106(10):1865–71. doi: 10.2105/ajph.2016.303362. PMID: 27552267.27552267
110 Whetstone LM, Kolasa KM, Collier DN. Participation in community-originated interventions is associated with positive changes in weight status and health behaviors in youth. Am J Health Promot. 2012 Sep–Oct;27(1):10–6. doi: 10.4278/ajhp.100415-QUAN-117. PMID: 22950920.22950920
111 Harding MC, Bott QD, Jonas CE. The Malaekahana Path: An Ecological Model-based Intervention for Increasing Walking in Rural Hawai’i. J Phys Act Health. 2017 Jul 06:1–11. doi: 10.1123/jpah.2017-0330. PMID: 28682662.28682662
112 Cohen DA, Marsh T, Williamson S, . Impact and cost-effectiveness of family Fitness Zones: a natural experiment in urban public parks. Health Place. 2012 Jan;18(1):39–45. doi: 10.1016/j.healthplace.2011.09.008. PMID: 22243905.22243905
113 Farley TA, Meriwether RA, Baker ET, . Safe play spaces to promote physical activity in inner-city children: results from a pilot study of an environmental intervention. Am J Public Health. 2007 Sep;97(9):1625–31. doi: 10.2105/ajph.2006.092692. PMID: 17666701.17666701
114 Toussaint LL, Housholder K, Janssen K, . Slowing BMI Growth Trajectories in Elementary School-Aged Children: The Northeast Iowa Food and Fitness Initiative. Fam Community Health. 2017 Jul/Sep;40(3):192–7. doi: 10.1097/fch.0000000000000151. PMID: 28525438.28525438
115 Morrill BA, Madden GJ, Wengreen HJ, . A Randomized Controlled Trial of the Food Dudes Program: Tangible Rewards are More Effective Than Social Rewards for Increasing Short- and Long-Term Fruit and Vegetable Consumption. J Acad Nutr Diet. 2016 Apr;116(4):618–29. doi: 10.1016/j.jand.2015.07.001. PMID: 26297598.26297598
116 Weaver RG, Webster CA, Egan C, . Partnerships for Active Children in Elementary Schools: Outcomes of a 2-Year Pilot Study to Increase Physical Activity During the School Day. Am J Health Promot. 2017 Jan 01:890117117707289. doi: 10.1177/0890117117707289. PMID: 28482678.28482678
117 Nanney MS, MacLehose R, Kubik MY, . Recommended school policies are associated with student sugary drink and fruit and vegetable intake. Prev Med. 2014 May;62:179–81. doi: 10.1016/j.ypmed.2014.01.026. PMID: 24518003.24518003
118 Backman D, Gonzaga G, Sugerman S, . Effect of fresh fruit availability at worksites on the fruit and vegetable consumption of low-wage employees. J Nutr Educ Behav. 2011 Jul–Aug;43(4 Suppl 2):S113–21. doi: 10.1016/j.jneb.2011.04.003. PMID: 21683280.21683280
119 Caballero B, Clay T, Davis SM, . Pathways: a school-based, randomized controlled trial for the prevention of obesity in American Indian schoolchildren. Am J Clin Nutr. 2003 Nov;78(5):1030–8. PMID: 14594792.14594792
120 Hilmers A, Chen TA, Dave JM, . Supplemental Nutrition Assistance Program participation did not help low income Hispanic women in Texas meet the dietary guidelines. Prev Med. 2014 May;62:44–8. doi: 10.1016/j.ypmed.2014.01.016. PMID: 24530319.24530319
121 Gorham G, Dulin-Keita A, Risica PM, . Effectiveness of Fresh to You, a Discount Fresh Fruit and Vegetable Market in Low-Income Neighborhoods, on Children’s Fruit and Vegetable Consumption, Rhode Island, 2010–2011. Prev Chronic Dis. 2015 Oct 15;12:E176. doi: 10.5888/pcd12.140583. PMID: 26469949.26469949
122 Cummins S, Flint E, Matthews SA. New neighborhood grocery store increased awareness of food access but did not alter dietary habits or obesity. Health Aff (Millwood). 2014 Feb;33(2):283–91. doi: 10.1377/hlthaff.2013.0512. PMID: 24493772.24493772
123 Branas CC, Cheney RA, MacDonald JM, . A difference-in-differences analysis of health, safety, and greening vacant urban space. Am J Epidemiol. 2011 Dec 01;174(11):1296–306. doi: 10.1093/aje/kwr273. PMID: 22079788.22079788
124 Ayala GX, Baquero B, Laraia BA, . Efficacy of a store-based environmental change intervention compared with a delayed treatment control condition on store customers’ intake of fruits and vegetables. Public Health Nutr. 2013 Nov;16(11):1953–60. doi: 10.1017/s1368980013000955. PMID: 23561842.23561842
125 Haerens L, Deforche B, Maes L, . Body mass effects of a physical activity and healthy food intervention in middle schools. Obesity (Silver Spring). 2006 May;14(5):847–54. doi: 10.1038/oby.2006.98. PMID: 16855194.16855194
126 Heelan KA, Abbey BM, Donnelly JE, . Evaluation of a Walking School Bus for Promoting Physical Activity in Youth. J Phys Act Health. 2009 Sep;6(5):560–7. PMID: 19953832.19953832
127 LaCaille LJ, Schultz JF, Goei R, . Go!: results from a quasi-experimental obesity prevention trial with hospital employees. BMC Public Health. 2016 Feb 19;16:171. doi: 10.1186/s12889-016-2828-0. PMID: 26893128.26893128
128 Kim J. Are physical education-related state policies and schools’ physical education requirement related to children’s physical activity and obesity? J Sch Health. 2012 Jun;82(6):268–76. doi: 10.1111/j.1746-1561.2012.00697.x. PMID: 22568462.22568462
129 Reger-Nash B, Bauman A, Booth-Butterfield S, . Wheeling walks: evaluation of a media-based community intervention. Fam Community Health. 2005 Jan–Mar;28(1):64–78. PMID: 15625507.15625507
130 Gebel K, Bauman AE, Reger-Nash B, . Does the environment moderate the impact of a mass media campaign to promote walking? Am J Health Promot. 2011 Sep–Oct;26(1):45–8. doi: 10.4278/ajhp.081104-ARB-269. PMID: 21879942.21879942
131 Jordan KC, Erickson ED, Cox R, . Evaluation of the Gold Medal Schools program. J Am Diet Assoc. 2008 Nov;108(11):1916–20. doi: 10.1016/j.jada.2008.08.002. PMID: 18954584.18954584
132 Quigg R, Reeder AI, Gray A, . The Effectiveness of a Community Playground Intervention. Journal of Urban Health-Bulletin of the New York Academy of Medicine. 2012 Feb;89(1):171–84. doi: 10.1007/s11524-011-9622-1.21959697
133 Tester JM, Leung CW, Crawford PB. Revised WIC Food Package and Children’s Diet Quality. Pediatrics. 2016 May;137(5)doi: 10.1542/peds.2015-3557. PMID: 27244804.27244804
134 Sekhobo JP, Edmunds LS, Dalenius K, . Neighborhood disparities in prevalence of childhood obesity among low-income children before and after implementation of New York City child care regulations. Prev Chronic Dis. 2014;11:E181. doi: 10.5888/pcd11.140152. PMID: 25321632.25321632
135 Nicklas T, Lopez S, Liu Y, . Motivational theater to increase consumption of vegetable dishes by preschool children. Int J Behav Nutr Phys Act. 2017 Feb 07;14(1):16. doi: 10.1186/s12966-017-0468-0. PMID: 28166788.28166788
136 Taber DR, Stevens J, Evenson KR, . State policies targeting junk food in schools: racial/ethnic differences in the effect of policy change on soda consumption. Am J Public Health. 2011 Sep;101(9):1769–75. doi: 10.2105/ajph.2011.300221. PMID: 21778484.21778484
137 Liu J, Kuo T, Jiang L, . Food and drink consumption among 1–5-year-old Los Angeles County children from households receiving dual SNAP and WIC v. only WIC benefits. Public Health Nutr. 2016 Sep 9:1–8. doi: 10.1017/s1368980016002329. PMID: 27609603.27609603
138 Olsho LE, Payne GH, Walker DK, . Impacts of a farmers’ market incentive programme on fruit and vegetable access, purchase and consumption. Public Health Nutr. 2015 Oct;18(15):2712–21. doi: 10.1017/s1368980015001056. PMID: 25919225.25919225
139 Te Velde SJ, Brug J, Wind M, . Effects of a comprehensive fruit- and vegetable-promoting school-based intervention in three European countries: the Pro Children Study. Br J Nutr. 2008 Apr;99(4):893–903. doi: 10.1017/s000711450782513x. PMID: 17953787.17953787
140 Nehme EK, Perez A, Ranjit N, . The Effect of New Shower Facilities on Physical Activity Behaviors of Employees: A Quasi-experiment. J Phys Act Health. 2017 Feb;14(2):98–107. doi: 10.1123/jpah.2015-0418. PMID: 27775466.27775466
141 Barnidge EK, Hipp PR, Estlund A, . Association between community garden participation and fruit and vegetable consumption in rural Missouri. Int J Behav Nutr Phys Act. 2013 Nov 19;10:128. doi: 10.1186/1479-5868-10-128. PMID: 24252563.24252563
142 Pope M. Preventing Weight Gain in Children Who Are School Age and African-American. Pediatr Phys Ther. 2016 Summer;28(2):207–16. doi: 10.1097/pep.0000000000000243. PMID: 26914717.26914717
143 Cawley J, Meyerhoefer C, Newhouse D. The impact of state physical education requirements on youth physical activity and overweight. Health Econ. 2007;16(12):1287–301. doi: 10.1002/hec.1218. PMID: 2007-19974-001.17328052
144 Cawley J, Meyerhoefer C, Newhouse D. The Correlation of Youth Physical Activity with State Policies. Contemporary Economic Policy. 2007;25(4):506–17. doi: http://onlinelibrary.wiley.com/journal/10.1111/%28ISSN%291465-7287. PMID: 0952344 Alternate Accession Number: EP27555031.0952344
145 Masse LC, de Niet-Fitzgerald JE, Watts AW, . Associations between the school food environment, student consumption and body mass index of Canadian adolescents. Int J Behav Nutr Phys Act. 2014 Mar 26;11(1):29. doi: 10.1186/1479-5868-11-29. PMID: 24666770.24666770
146 Eagle TF, Gurm R, Smith CA, . A middle school intervention to improve health behaviors and reduce cardiac risk factors. Am J Med. 2013 Oct;126(10):903–8. doi: 10.1016/j.amjmed.2013.04.019. PMID: 23932159.23932159
147 Peterson KE, Spadano-Gasbarro JL, Greaney ML, . Three-Year Improvements in Weight Status and Weight-Related Behaviors in Middle School Students: The Healthy Choices Study. PLoS One. 2015;10(8):e0134470. doi: 10.1371/journal.pone.0134470. PMID: 26295837.26295837
148 Ortega AN, Albert SL, Chan-Golston AM, . Substantial improvements not seen in health behaviors following corner store conversions in two Latino food swamps. BMC Public Health. 2016 May 11;16:389. doi: 10.1186/s12889-016-3074-1. PMID: 27169514.27169514
149 Frongillo EA, Fawcett SB, Ritchie LD, . Community Policies and Programs to Prevent Obesity and Child Adiposity. Am J Prev Med. 2017 Jul 05doi: 10.1016/j.amepre.2017.05.006. PMID: 28688728.28688728
150 Goldsby TU, George BJ, Yeager VA, . Urban Park Development and Pediatric Obesity Rates: A Quasi-Experiment Using Electronic Health Record Data. Int J Environ Res Public Health. 2016 Apr 08;13(4):411. doi: 10.3390/ijerph13040411. PMID: 27070635.27070635
151 Baker EA, Barnidge EK, Schootman M, . Adaptation of a Modified DASH Diet to a Rural African American Community Setting. Am J Prev Med. 2016 Sep 12doi: 10.1016/j.amepre.2016.07.014. PMID: 27633485.27633485
152 Huberty J, Beets M, Beighle A. Effects of a policy-level intervention on children’s pedometer-determined physical activity: preliminary findings from Movin’ Afterschool. J Public Health Manag Pract. 2013 Nov–Dec;19(6):525–8. doi: 10.1097/PHH.0b013e31829465fa. PMID: 23676476.23676476
153 Pate RR, Ward DS, Saunders RP, . Promotion of physical activity among high-school girls: a randomized controlled trial. Am J Public Health. 2005 Sep;95(9):1582–7. doi: 10.2105/ajph.2004.045807. PMID: 16118370.16118370
154 Pbert L, Druker S, Barton B, . A School-Based Program for Overweight and Obese Adolescents: A Randomized Controlled Trial. J Sch Health. 2016 Oct;86(10):699–708. doi: 10.1111/josh.12428. PMID: 27619760.27619760
155 Cheadle A, Rauzon S, Spring R, . Kaiser Permanente ’s Community Health Initiative in Northern California: evaluation findings and lessons learned. Am J Health Promot. 2012 Nov–Dec;27(2):e59–68. doi: 10.4278/ajhp.111222-QUAN-462. PMID: 23113787.23113787
156 Madsen KA, Cotterman C, Crawford P, . Effect of the healthy schools program on prevalence of overweight and obesity in California schools, 2006–2012. Preventing Chronic Disease: Public Health Research, Practice, and Policy. 2015;12 PMID: 2016-24674-001.
157 de Visser R, Sylvester R, Rogers R, . Changes in School Health Program Improve Middle School Students’ Behaviors. Am J Health Behav. 2016 Sep;40(5):568–77. doi: 10.5993/ajhb.40.5.3. PMID: 27561859.27561859
158 Wright K, Giger JN, Norris K, . Impact of a nurse-directed, coordinated school health program to enhance physical activity behaviors and reduce body mass index among minority children: a parallel-group, randomized control trial. Int J Nurs Stud. 2013 Jun;50(6):727–37. doi: 10.1016/j.ijnurstu.2012.09.004. PMID: 23021318.23021318
159 Berger-Jenkins E, Rausch J, Okah E, . Evaluation of a Coordinated School-Based Obesity Prevention Program in a Hispanic Community: Choosing Healthy and Active Lifestyles for Kids/Healthy Schools Healthy Families. American Journal of Health Education. 2014;45(5):261–70. doi: 10.1080/19325037.2014.932724. PMID: 103883129. Language: English. Entry Date: 20140909. Revision Date: 20150820. Publication Type: Journal Article.
160 Hollis JL, Sutherland R, Campbell L, . Effects of a ‘school-based’ physical activity intervention on adiposity in adolescents from economically disadvantaged communities: secondary outcomes of the ‘Physical Activity 4 Everyone’ RCT. Int J Obes (Lond). 2016 Oct;40(10):1486–93. doi: 10.1038/ijo.2016.107. PMID: 27430652.27430652
161 Herrick H, Thompson H, Kinder J, . Use of SPARK to promote after-school physical activity. J Sch Health. 2012 Oct;82(10):457–61. doi: 10.1111/j.1746-1561.2012.00722.x. PMID: 22954164.22954164
162 Wilson DK, Van Horn ML, Siceloff ER, . The Results of the “Positive Action for Today’s Health” (PATH) Trial for Increasing Walking and Physical Activity in Underserved African-American Communities. Ann Behav Med. 2015 Jun;49(3):398–410. doi: 10.1007/s12160-014-9664-1. PMID: 25385203.25385203
163 Dubowitz T, Ghosh-Dastidar M, Cohen DA, . Diet And Perceptions Change With Supermarket Introduction In A Food Desert, But Not Because Of Supermarket Use. Health Aff (Millwood). 2015 Nov;34(11):1858–68. doi: 10.1377/hlthaff.2015.0667. PMID: 26526243.26526243
164 Coleman KJ, Shordon M, Caparosa SL, . The healthy options for nutrition environments in schools (Healthy ONES) group randomized trial: using implementation models to change nutrition policy and environments in low income schools. Int J Behav Nutr Phys Act. 2012 Jun 27;9:80. doi: 10.1186/1479-5868-9-80. PMID: 22734945.22734945
165 Neumark-Sztainer DR, Friend SE, Flattum CF, . New moves-preventing weight-related problems in adolescent girls a group-randomized study. Am J Prev Med. 2010 Nov;39(5):421–32. doi: 10.1016/j.amepre.2010.07.017. PMID: 20965379.20965379
166 Bastian KA, Maximova K, McGavock J, . Does School-Based Health Promotion Affect Physical Activity on Weekends? And, Does It Reach Those Students Most in Need of Health Promotion? PLoS One. 2015;10(10):e0137987. doi: 10.1371/journal.pone.0137987. PMID: 26488168.26488168
167 Linde JA, Nygaard KE, MacLehose RF, . HealthWorks: results of a multi-component group-randomized worksite environmental intervention trial for weight gain prevention. Int J Behav Nutr Phys Act. 2012 Feb 16;9:14. doi: 10.1186/1479-5868-9-14. PMID: 22340088.22340088
168 Simon C, Schweitzer B, Oujaa M, . Successful overweight prevention in adolescents by increasing physical activity: a 4-year randomized controlled intervention. Int J Obes (Lond). 2008 Oct;32(10):1489–98. doi: 10.1038/ijo.2008.99. PMID: 18626482.18626482
169 Madsen K, Linchey J, Gerstein D, . Energy Balance 4 Kids with Play: Results from a Two-Year Cluster-Randomized Trial. Child Obes. 2015 Aug;11(4):375–83. doi: 10.1089/chi.2015.0002. PMID: 26061799.26061799
170 Gustat J, Rice J, Parker KM, . Effect of changes to the neighborhood built environment on physical activity in a low-income African American neighborhood. Prev Chronic Dis. 2012;9:E57. PMID: 22338597.22338597
171 Madsen K, Thompson H, Adkins A, . School-community partnerships: a cluster-randomized trial of an after-school soccer program. JAMA Pediatr. 2013 Apr;167(4):321–6. doi: 10.1001/jamapediatrics.2013.1071. PMID: 23440308.23440308
172 Lent MR, Vander Veur SS, McCoy TA, . A randomized controlled study of a healthy corner store initiative on the purchases of urban, low-income youth. Obesity (Silver Spring). 2014 Dec;22(12):2494–500. doi: 10.1002/oby.20878. PMID: 25311881.25311881
173 de Silva-Sanigorski A, Elea D, Bell C, . Obesity prevention in the family day care setting: impact of the Romp & Chomp intervention on opportunities for children’s physical activity and healthy eating. Child Care Health Dev. 2011 May;37(3):385–93. doi: 10.1111/j.1365-2214.2010.01205.x. PMID: 21276039.21276039
174 Perry CL, Bishop DB, Taylor GL, . A randomized school trial of environmental strategies to encourage fruit and vegetable consumption among children. Health Educ Behav. 2004 Feb;31(1):65–76. PMID: 14768658.14768658
175 Dunton G, Ebin VJ, Efrat MW, . The Use of Refundable Tax Credits to Increase Low-Income Children’s After-School Physical Activity Level. J Phys Act Health. 2015 Jun;12(6):840–53. doi: 10.1123/jpah.2014-0058. PMID: 25184738.25184738
176 Gittelsohn J, Vijayadeva V, Davison N, . A food store intervention trial improves caregiver psychosocial factors and children’s dietary intake in Hawaii. Obesity (Silver Spring). 2010 Feb;18 Suppl 1:S84–90. doi: 10.1038/oby.2009.436. PMID: 20107467.20107467
177 Cohen JF, Kraak VI, Choumenkovitch SF, . The CHANGE study: a healthy-lifestyles intervention to improve rural children’s diet quality. J Acad Nutr Diet. 2014 Jan;114(1):48–53. doi: 10.1016/j.jand.2013.08.014. PMID: 24126295.24126295
178 Burke RM, Meyer A, Kay C, . A holistic school-based intervention for improving health-related knowledge, body composition, and fitness in elementary school students: an evaluation of the HealthMPowers program. Int J Behav Nutr Phys Act. 2014 Jun 26;11:78. doi: 10.1186/1479-5868-11-78. PMID: 24969618.24969618
179 Chomitz VR, McGowan RJ, Wendel JM, . Healthy Living Cambridge Kids: a community-based participatory effort to promote healthy weight and fitness. Obesity (Silver Spring). 2010 Feb;18 Suppl 1:S45–53. doi: 10.1038/oby.2009.431. PMID: 20107461.20107461
180 Beresford SA, Thompson B, Bishop S, . Long-term fruit and vegetable change in worksites: Seattle 5 a Day follow-up. Am J Health Behav. 2010 Nov–Dec;34(6):707–20. PMID: 20604696.20604696
181 Lemon SC, Wang ML, Wedick NM, . Weight gain prevention in the school worksite setting: results of a multi-level cluster randomized trial. Prev Med. 2014 Mar;60:41–7. doi: 10.1016/j.ypmed.2013.12.010. PMID: 24345602.24345602
182 Economos CD, Hyatt RR, Goldberg JP, . A community intervention reduces BMI z-score in children: Shape Up Somerville first year results. Obesity (Silver Spring). 2007 May;15(5):1325–36. doi: 10.1038/oby.2007.155. PMID: 17495210.17495210
183 Goetzel RZ, Roemer EC, Pei X, . Second-year results of an obesity prevention program at the Dow Chemical Company. J Occup Environ Med. 2010 Mar;52(3):291–302. doi: 10.1097/JOM.0b013e3181d46f0b. PMID: 20190646.20190646
184 Rogers VW, Hart PH, Motyka E, . Impact of Let’s Go! 5-2-1-0: a community-based, multisetting childhood obesity prevention program. J Pediatr Psychol. 2013 Oct;38(9):1010–20. doi: 10.1093/jpepsy/jst057. PMID: 23933841.23933841
185 Jurg ME, Kremers SP, Candel MJ, . A controlled trial of a school-based environmental intervention to improve physical activity in Dutch children: JUMP-in, kids in motion. Health Promot Int. 2006 Dec;21(4):320–30. doi: 10.1093/heapro/dal032. PMID: 16963784.16963784
186 Reger-Nash B, Bauman A, Cooper L, . WV Walks: replication with expanded reach. J Phys Act Health. 2008 Jan;5(1):19–27. PMID: 18209251.18209251