# Appendix E Data System Classification/Coding Schema

Data System Specs and Meta Info
Data System Definition
Exists | [Y/N]
Accessible | [Y/N]
Sharable | [Y/N]
Outcome | [Y/N]
Qualifies | [Y/N]
US vs Non-US
Non-US | [Y/N]
Country | [TXT]
Data System Type
Primary | [Y/N]
Non-sharable | [Y/N]
Sharable | [Y/N]
Secondary | [Y/N]
Data System Meta
Database Name | [TXT]
Database Abbreviation | [TXT]
Data Custodian/Owner Name | [TXT]
Data Custodian Abbreviation | [TXT]
Web Links (URL)
Generic/Dedicated Website | [URL]
Data Dictionary | [URL]
Download (e.g., public use file) | [URL]
Parent System (e.g., national system) | [URL]
Additional Links #1 | [URL]
Additional Links #2 | [URL]
Additional Links #3 | [URL]
Data System Information Availability
Dedicated Web Page | [Y/N]
Summary of Data System (e.g., description and purpose) | [Y/N]
Some Detailed Information (e.g., data elements) | [Y/N]
Very Detailed Information (e.g., data quality reports) | [Y/N]
Data Accessible (free or for a fee) | [Y/N]
Publicly Available (e.g., public use file with download link) | [Y/N]
Requires Automated Registration (e.g., signing up) | [Y/N]
Requires Manual Confirmation (e.g., email request) | [Y/N]
Data Dictionary (any level) | [Y/N]
Formal Data Dictionary (e.g., XML, PDF) | [Y/N]
Informal Data Dictionary (e.g., survey questions) | [Y/N]
Proxy Data Dictionary (e.g., summary reports) | [Y/N]
Data Use and Functions
Purpose | [TXT]
Research | [Y/N]
Clinical | [Y/N]
Administrative | [Y/N]
Pub Health | [Y/N]
Other | [TXT]
Geographic Coverage
Countries
Country | [TXT]
U.S.-based | [Y/N]
Other (e.g., multi-country) | [TXT]
U.S. Coverage
Setting | [TXT]
National | [Y/N]
Regional (e.g., east coast) | [Y/N]
State-level | [Y/N]
Area (smaller than state) | [Y/N]
County or City-level | [Y/N]
Zip code or Census Tract | [Y/N]
Smaller than Census Tract (e.g., Block Group) | [Y/N]
Other (e.g., territory) | [Y/N]
U.S. States
Alabama (AL) | [Y/N]
Alaska (AK) | [Y/N]
Arizona (AZ) | [Y/N]
Arkansas (AR) | [Y/N]
California (CA) | [Y/N]
Colorado (CO) | [Y/N]
Connecticut (CT) | [Y/N]
Delaware (DE) | [Y/N]
Florida (FL) | [Y/N]
Georgia (GA) | [Y/N]
Hawaii (HI) | [Y/N]
Idaho (ID) | [Y/N]
Illinois (IL) | [Y/N]
Indiana (IN) | [Y/N]
Iowa (IA) | [Y/N]
Kansas (KS) | [Y/N]
Kentucky (KY) | [Y/N]
Louisiana (LA) | [Y/N]
Maine (ME) | [Y/N]
Maryland (MD) | [Y/N]
Massachusetts (MA) | [Y/N]
Michigan (MI) | [Y/N]
Minnesota (MN) | [Y/N]
Mississippi (MS) | [Y/N]
Missouri (MO) | [Y/N]
Montana (MT) | [Y/N]
Nebraska (NE) | [Y/N]
Nevada (NV) | [Y/N]
New Hampshire (NH) | [Y/N]
New Jersey (NJ) | [Y/N]
New Mexico (NM) | [Y/N]
New York (NY) | [Y/N]
North Carolina (NC) | [Y/N]
North Dakota (ND) | [Y/N]
Ohio (OH) | [Y/N]
Oklahoma (OK) | [Y/N]
Oregon (OR) | [Y/N]
Pennsylvania (PA) | [Y/N]
Rhode Island (RI) | [Y/N]
South Carolina (SC) | [Y/N]
South Dakota (SD) | [Y/N]
Tennessee (TN) | [Y/N]
Texas (TX) | [Y/N]
Utah (UT) | [Y/N]
Vermont (VT) | [Y/N]
Virginia (VA) | [Y/N]
Washington (WA) | [Y/N]
West Virginia (WV) | [Y/N]
Wisconsin (WI) | [Y/N]
Wyoming (WY) | [Y/N]
Other (e.g., islands, territories) | [Y/N]
Demographic Coverage
Population Denominator
General Population | [Y/N]
Community level | [Y/N]
Schools | [Y/N]
Programs | [Y/N]
Households | [Y/N]
Other | [Y/N]
Age Coverage
Age Range (text/numerical) | [Y/N]
Infant | [Y/N]
Preschool | [Y/N]
Elementary School | [Y/N]
Middle School | [Y/N]
High School | [Y/N]
Teen/Adolescent/Youth (not bound to school age) | [Y/N]
Adult | [Y/N]
Gender
Male | [Y/N]
Female | [Y/N]
Other Demographics
Socio-economic Status | [Y/N]
Ethnicity | [Y/N]
Race | [Y/N]
Data Granularity
Aggregation Unit
Individual | [Y/N]
Aggregated | [Y/N]
Demographic | [Y/N]
Geographic | [Y/N]
Entity
Payer | [Y/N]
Provider | [Y/N]
Employer | [Y/N]
Educational Institute (e.g., school) | [Y/N]
Other | [TXT]
Outcomes/Variables of Interest
Primary Outcomes | [Y/N]
Weight | [Y/N]
Height | [Y/N]
BMI | [Y/N]
Diet | [Y/N]
Physical Activity | [Y/N]
Secondary [Intermediate] Outcome | [Y/N]
Policy | [Y/N]
Program | [Y/N]
Build Environment | [Y/N]
Other Geographical Information | [Y/N]
Data System Scalability
Data Linkage
Linked | [Y/N]
Linked Data (i.e., external DB names) | [TXT]
Linked Method | [TXT]
Data Collection Method
Collection Method | [TXT]
Survey (self-report) | [Y/N]
EHR/EMR (any medical record) | [Y/N]
Panel/Longitudinal (cohort) | [Y/N]
Cross-sectional | [Y/N]
Other (objective measure) | [Y/N]
Data Updates
Ongoing | [Y/N]
Stopped | [Y/N]
Year Started | [YYYY]
Year Stopped | [YYYY]
Data Governance
Data Access
Unrestricted | [Y/N]
Public Use File Link | [URL]
Registration Required | [Y/N]
Data Commodity
Free | [Y/N]
Fee | [Y/N]
Other (e.g., special licensing structure) | [Y/N]
Data Privacy (HIPAA Status)
Compliant
Limited
Protected