# Appendix D Abstraction Forms

Figure D1 Abstract screening form

Figure D1 is a screenshot of the DistillerSR form used to screen abstracts for inclusion or exclusion in the report.

Figure D2 Article screening form

Figure D2 is a screenshot of the DistillerSR form used to screen full text articles for inclusion or exclusion in the report.

Figure D3 Data source abstraction form

Figure D3 is a screenshot of the DistillerSR form used to abstract data source information from articles included in this review.

Figure D4 Design specific abstraction form

Figure D4 is a screenshot of the DistillerSR form used to abstract specific information about study design, and analytic approach from articles included in this review.

Figure D5 Study and participant characteristics abstraction form

Figure D5 is a screenshot of the DistillerSR form used to abstract specific study and participant characteristics from the included articles including study dates, community, setting, and baseline participant characteristics.

Figure D6 Intervention abstraction form

Figure D6 is a screenshot of the DistillerSR form used to abstract information about the interventions from the included studies including program/policy/built environment change, whether or not the study evaluated a policy, and if the policy is national, regional, local, or non-US based.

Figure D7 General outcomes abstraction form

Figure D7 is a screenshot of the DistillerSR form used to abstract information about the general outcomes included in each study including weight outcomes (change in weight and BMI for adults; BMI z-score, BMI percentile, weight change, and weigh percentile in children); change in total caloric intake; change in fruit and vegetable intake; change in fiber intake; change in sugar sweetened beverage intake; change in fast-food intake; change in physical activity; change in commuting behavior; change in purchasing behavior; and urban renewal. Information on subgroups was collected when applicable. Impact of the intervention on the outcome was also abstracted.

Figure D8 Future research needs abstraction form

Figure D8 is a screenshot of the DistillerSR form used to abstract information about future research needs specified by the individual article authors.

Figure D9 Risk of bias abstraction form

Figure D9 is a screenshot of the DistillerSR form used to abstract information about individual study risk of bias including selection bias, study design, confounders, blinding, data collection methods, withdrawals and drop-outs, intervention integrity, and analyses.