# Appendix C Detailed Search Strategies

Table C1 PubMed search strategy

# | Term/string
1 | obesity[mh]
2 | obese[tiab]
3 | obesity[tiab]
4 | overweight[tiab]
5 | “over weight”[tiab]
6 | BMI[tiab]
7 | “body mass index”[tiab]
8 | “Body mass index”[mh]
9 | 1 OR 2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8
10 | “Policy”[Mesh]
11 | policy[tiab]
12 | policies[tiab]
13 | law[tiab]
14 | Purchasing[tiab]
15 | Purchases[tiab]
16 | “food labeling”[mh]
17 | “calorie information”[tiab]
18 | “calorie labeling”[tiab]
19 | Environment[tiab]
20 | 10 OR 11 OR 12 OR 13 OR 14 OR 15 OR 16 OR 17 OR 18 OR 19
21 | 9 AND 20
| Date limited: 2000 to present

Table C2 CINAHL/PsycINFO/EconLit search strategy

Results from 4 November 2016

Search ID# | Search Terms | Search Options
S48 | S33 AND S46 | Limiters - Published Date: 20000101-20161031; Exclude MEDLINE records; Publication Year: 2000–2016; Exclude Dissertations Search modes - Boolean/Phrase
S47 | S33 AND S46 | Search modes - Boolean/Phrase
S46 | S34 OR S35 OR S36 OR S37 OR S38 OR S39 OR S40 OR S41 OR S42 OR S43 OR S44 OR S45 | Search modes - Boolean/Phrase
S45 | TI environment OR AB environment | Search modes - Boolean/Phrase
S44 | TI “calorie labeling” OR AB “calorie labeling” | Search modes - Boolean/Phrase
S43 | TI “caloric information” OR AB “caloric information” | Search modes - Boolean/Phrase
S42 | TI “calorie information” OR AB “calorie information” | Search modes - Boolean/Phrase
S41 | TI “food labeling” OR AB “food labeling” | Search modes - Boolean/Phrase
S40 | TI purchases OR AB purchases | Search modes - Boolean/Phrase
S39 | TI purchasing OR AB purchasing | Search modes - Boolean/Phrase
S38 | TI law OR AB law | Search modes - Boolean/Phrase
S37 | TI policies OR AB policies | Search modes - Boolean/Phrase
S36 | TI policy OR AB policy | Search modes - Boolean/Phrase
S35 | (MH “Food Labeling+”) | Search modes - Boolean/Phrase
S34 | (MH “Public Policy+”) | Search modes - Boolean/Phrase
S33 | S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 | Search modes - Boolean/Phrase
S32 | TI BMI OR AB BMI | Search modes - Boolean/Phrase
S31 | TI “body mass index” OR AB “body mass index” | Search modes - Boolean/Phrase
S30 | TI “over weight” OR AB “over weight” | Search modes - Boolean/Phrase
S29 | TI overweight OR AB overweight | Search modes - Boolean/Phrase
S28 | TI obese OR AB obese | Search modes - Boolean/Phrase
S27 | TI obesity OR AB obesity | Search modes - Boolean/Phrase
S26 | (MH “body mass index+”) | Search modes - Boolean/Phrase
S25 | (MH “Obesity+”) | Search modes - Boolean/Phrase
S24 | S9 AND S22 | Limiters - Published Date: 20000101-20161031; Exclude MEDLINE records; Publication Year: 2000–2016; Exclude Dissertations Search modes - Boolean/Phrase
S23 | S9 AND S22 | Search modes - Boolean/Phrase
S22 | S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 | Search modes - Boolean/Phrase
S21 | TI environment OR AB environment | Search modes - Boolean/Phrase
S20 | TI “calorie labeling” OR AB “calorie labeling” | Search modes - Boolean/Phrase
S19 | TI “caloric information” OR AB “caloric information” | Search modes - Boolean/Phrase
S18 | TI “calorie information” OR AB “calorie information” | Search modes - Boolean/Phrase
S17 | TI “food labeling” OR AB “food labeling” | Search modes - Boolean/Phrase
S16 | TI purchases OR AB purchases | Search modes - Boolean/Phrase
S15 | TI purchasing OR AB purchasing | Search modes - Boolean/Phrase
S14 | TI law OR AB law | Search modes - Boolean/Phrase
S13 | TI policies OR AB policies | Search modes - Boolean/Phrase
S12 | TI policy OR AB policy | Search modes - Boolean/Phrase
S11 | (MH “Food Labeling+”) | Search modes - Boolean/Phrase
S10 | (MH “Public Policy+”) | Search modes - Boolean/Phrase
S9 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 | Search modes - Boolean/Phrase
S8 | TI BMI OR AB BMI | Search modes - Boolean/Phrase
S7 | TI “body mass index” OR AB “body mass index” | Search modes - Boolean/Phrase
S6 | TI “over weight” OR AB “over weight” | Search modes - Boolean/Phrase
S5 | TI overweight OR AB overweight | Search modes - Boolean/Phrase
S4 | TI obese OR AB obese | Search modes - Boolean/Phrase
S3 | TI obesity OR AB obesity | Search modes - Boolean/Phrase
S2 | (MH “body mass index+”) | Search modes - Boolean/Phrase
S1 | (MH “Obesity+”) | Search modes - Boolean/Phrase

Table C3 Supplemental search strategy (PubMed)

# | Term/string
1 | Exercise[mh]
2 | exercise[tiab]
3 | “physical activity”[tiab]
4 | “motor activity”[mh]
5 | “motor activity”[tiab]
6 | “energy metabolism”[mh]
7 | “energy expenditure”[tiab]
8 | diet[mh]
9 | diet[tiab]
10 | dietary[tiab]
11 | “energy intake”[mh]
12 | “caloric intake”[tiab]
13 | calories[tiab]
14 | fruit[tiab]
15 | vegetable[tiab]
16 | “sugar sweetened beverage”[tiab]
17 | SSB[tiab]
18 | “fast foods”[mh]
19 | “fast food”[tiab]
20 | “fast foods”[tiab]
21 | intake[tiab]
22 | consumption[tiab]
23 | 13 OR 14 OR 15 OR 16 OR 17 OR 18 OR 19 OR 20
24 | 21 OR 22
25 | 23 AND 24
26 | 1 OR 2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8 OR 9 OR 10 OR 11 OR 12
27 | 26 OR 25
28 | “Transportation”[Mesh]
29 | transportation[tiab]
30 | transit[tiab]
31 | recreation[Mesh]
32 | recreation[tiab]
33 | “Environment Design”[Mesh]
34 | “Walking”[Mesh]
35 | walk[tiab]
36 | walking[tiab]
37 | “Bicycling”[Mesh]
38 | bike[tiab]
39 | bicycling[tiab]
40 | biking
41 | greening[tiab]
42 | 28 OR 29 OR 30 OR 31 OR 32 OR 33 OR 34 OR 35 OR 36 OR 37 OR 38 OR 39 OR 40 OR 41
43 | 27 AND 42
| Limit to systematic reviews AND limit to 2013 through 2017