# Appendix B Glossary of Key Terms

24-hour dietary recall: 24-hour dietary recall is aimed at capturing a comprehensive and detailed accounting of all foods, beverages, and in some cases, supplements, consumed on a given day. Traditionally, 24-hour recalls have been administered by an interviewer. Multiple-pass methods are used to improve accuracy and may be implemented using computerized systems.^1^
BMI z-score: Number of standard deviations away from the population mean body mass index (BMI); in other words, the degree to which an individual’s measurement deviates from what is expected for that individual.
Body mass index (BMI): An indirect measure of body fat, calculated as the ratio of a person’s body weight in kilograms to the square of a person’s height in meters. BMI (kg/m^2^) = weight (kilograms) ÷ height (meters)^2^ BMI (lb/in^2^) = weight (pounds) ÷ height (inches)^2^ × 703 In children and youth, BMI is interpreted using growth charts for age and gender and is referred to as BMI-for-age and sex, which is used to assess underweight, overweight, and obesity. According to the Centers for Disease Control and Prevention (CDC), a child with a BMI that is equal to or greater than the 95th percentile is considered to be obese. A child with a BMI that is equal to or between the 85th and 95th percentile is considered to be overweight.^2^
Calorie: A calorie is defined as the amount of heat required to change the temperature of one gram of water from 14.5 degrees Celsius to 15.5 degrees Celsius. In this report, “calorie” is used synonymously with “kilocalorie,” the unit of measure for energy obtained from food and beverages.
Case control study: A retrospective study design where the investigators gather ‘cases’ of people who already have the outcome of interest and ‘controls’ who do not. Both groups are then questioned or their records examined about whether they received the intervention exposure of interest.^3^
Changes in the Built Environment: Built environments are the totality of places built or designed by humans, including buildings, grounds around buildings, layout of communities, transportation infrastructure, and parks and trails.^4^
  [underlined: Note]: examples include supermarkets, farmer’s markets, as well as infrastructure
Cohort (one group pre + post (before and after): The same group is pretested, given an intervention, and tested immediately after the intervention. The intervention group, by means of the pretest, act as their own control group.^3^
Cohort analytic (two group pre and post): An observational study design where groups are assembled according to whether or not exposure to the intervention has occurred. Exposure to the intervention is not under the control of the investigators. Study groups might be nonequivalent or not comparable on some feature that affects outcome.^3^
Competitive: Foods and beverages offered at schools other than meals and foods snacks served through the federally reimbursed school lunch, breakfast, and after-school snack programs. Competitive foods includes food and beverages items sold through à la carte lines, snack bars, student stores, vending machines, and school fundraisers.
Controlled Clinical Trial (CCT): An experimental study design where the method of allocating study subjects to intervention or control groups is open to individuals responsible for recruiting subjects or providing the intervention. The method of allocation is transparent before assignment, e.g. an open list of random numbers or allocation by date of birth, etc.^3^
Data source: Datasets, including both primary and secondary sources.
Data system: A data system involves the systematic collection of data, such as in a database, as well as the information technology infrastructure to maintain and operate the system.^5^
Electronic health record (EHR): A digital version of a patient’s paper chart. EHRs are real-time, patient-centered records that make information available instantly and securely to authorized users. While an EHR does contain the medical and treatment histories of patients, an EHR system is built to go beyond standard clinical data collected in a provider’s office and can be inclusive of a broader view of a patient’s care.^6^
Environment: The external influences on the life of an individual or community.
Food frequency questionnaires (FFQ): Food frequency questionnaires gather information about the frequency with which different foods and beverages are consumed over some period of time, often the last month or year. They may capture total diet or particular aspects of the diet. A questionnaire aimed at capturing total diet can be lengthy, requiring 30–60 minutes to complete.^1^
Food records/diaries: Food records or diaries (referred to as records subsequently, for simplicity) are intended to capture a detailed account of all foods, beverages, and possibly, supplements consumed on one or more days. Records are often kept for a period of one, three, or seven days. The distinction between recalls and records is that with a recall, the respondent reports (i.e., recalls, relying on memory) what was consumed yesterday (or over the past 24 hours) whereas with a record, the respondent keeps track of (i.e., records in real time) what he or she consumes.
Interrupted time series: A time series consists of multiple observations over time. Observations can be on the same units (e.g. individuals over time) or on different but similar units (e.g. student achievement scores for particular grade and school). Interrupted time series analysis requires knowing the specific point in the series when an intervention occurred.^3^
Messaging about nutrition and/or physical activity: [underlined: Consistent with the 2012 IOM Report that described “Message Environments”, policies and programs were classified as having specific messages or information about nutrition and/or physical activity (e.g. posted flyers or informational campaigns), which included social marketing strategies.^7^]
Natural experiment: Natural experiment refers to ways of evaluating policy, programmatic and environmental interventions using unplanned variation in exposure to assess the impact on health outcomes. The key features of these definitions are that: (1) the intervention (policy, program, environment change) is not undertaken for the purposes of research; and (2) the variation in exposure and outcomes is analyzed using methods that attempt to make causal inferences. Outside of a randomized controlled trial it is rare for variation in exposure to an intervention to be random, so special care is needed in the design, reporting and interpretation of evidence from natural experimental. Definition adapted from Craig, 2012.^8^
Obesity: An excess amount of subcutaneous body fat in proportion to lean body mass. In adults, a BMI of 30 or greater is considered obese. In this report, obesity in children and adolescents refers to age- and sex-specific BMIs that are equal to or greater than the 95th percentile of the CDC BMI growth charts. In most children, these values are known to indicate elevated body fat and to reflect the comorbidities associated with excessive body fatness.
Observation (physical activity): Direct observation is considered to be a gold standard method of physical activity assessment because behavior is directly observed. Observation typically involves the choice of a participant to observe (because it is not possible to observe all participants at the same time), when to watch (because it is not practical to try to observe continuously for extended periods), and how to record the behavior.^9^
Physical activity: Moderate- On an absolute scale, moderate-intensity physical activity is intensity completed at 3.0 to 5.9 times the intensity of rest. On a scale physical activity that is relative to an individual’s personal capacity, moderate intensity physical activity is usually a 5 or 6 on a scale of 0 to 10.
  Vigorous- On an absolute scale, vigorous-intensity physical activity is intensity completed at 6.0 or more times the intensity of rest. On a scale physical activity relative to an individual’s personal capacity, vigorous-intensity physical activity is usually a 7 or 8 on a scale of 0 to 10.
Policy: is broadly defined to include both formal public policies at local, state and federal levels of government, and organizational level policies, such as those implemented by large organizations, worksites or school districts. Examples include, but are not limited to, the development of supermarkets in underserved areas, calorie labeling requirements, taxes on foods and/or beverages, after-school and summer programs, modification of the built (or human-made) environments to encourage walking or cycling for transportation or leisure.^10^
Population-based: Individuals sampled are broadly representative of the targeted, general population, such as the neighborhood or children in a school system. In this review, obesity prevention and control policies and programs broadly target adults and/or children and the communities they live in.
Prevention: With regard to obesity,
  - primary prevention represents avoiding the occurrence of obesity in a population
  - secondary prevention represents early detection of disease through screening with the purpose of limiting its occurrence
  - tertiary prevention involves preventing the sequelae of obesity in childhood and adulthood.
Program: Set of activities initiated by governmental or other organizational bodies to enhance obesity prevention and control. Examples might include programs implemented worksites, healthcare organizations, after-school or summer programs, or communities that can be expected to improve obesity related behaviors such as energy intake and activity level. ^10^
Randomized controlled trial (RCT): An experimental design where investigators randomly allocate eligible people to an intervention or control group. A rater should describe a study as an RCT if the randomization sequence allows each study participant to have the same chance of receiving each intervention and the investigators could not predict which intervention was next.^3^
Rural: Relating to the country or countryside. In this report populations were designated “rural” by study authors, or not defined. The systematic review study group did not define these populations.
Questionnaires (diet): Brief instruments that enable the collection of basic information about particular foods or beverages or other dietary behaviors. Screeners may query the frequency of intake of certain foods or beverages and thus may be thought of as short food frequency questionnaires, usually without questions regarding portion sizes.^1^
Questionnaires (Physical Activity): include various self-report surveys, such as physical activity questionnaires and diaries, that capture a participant’s perception and interpretation of physical activity behavior. These tools also can be defined as subjective measures because they rely on the person’s ability to interpret and recall physical activity and are generally categorized by mode of administration: self-administered or interview (most are self-administered).^9^
Suburban: An outlying area adjacent to a city or town. In this report populations were designated “suburban” by study authors, or not defined. The systematic review study group did not define these populations.
Urban: Relating to or a characteristic of a city. In this report populations were designated “urban” by study authors, or not defined. The systematic review study group did not define these populations.
Wearable technology: A category of technology devices that can be worn by a consumer and often include tracking information related to health and fitness.^11^

## Appendix B References

1 Measures Registry User Guides: Overview of Individual Diet Measures. National Collaborative on Childhood Obesity Research; 2016. http://www.nccor.org/tools-mruserguides/individual-diet/overview-of-individual-diet-measures/#objective. Accessed on October 31, 2017.
2 About Child & Teen BMI. Atlants, GA: Centers for Disease Control and Prevention; 2015. https://www.cdc.gov/healthyweight/assessing/bmi/childrens_bmi/about_childrens_bmi.html. Accessed on August 11, 2017.
3 EPHPP: Quality Assessment Tool for Quantitative Studies Dictionary. Effective Public Health Practice Project. http://www.ephpp.ca/PDF/QADictionary_dec2009.pdf. Accessed on November 1, 2017.
4 Transportation Research Board and Institute of Medicine. Does the Built Environment Influence Physical Activity? Examining the evidence. Special Report 282. National Academies Press. Washington, DC: 2005. http://onlinepubs.trb.org/onlinepubs/sr/sr282.pdf
5 Wilcox H, Wissow L, Kharrazi H, . Data Linkage Strategies To Advance Youth Suicide Prevention. Evidence Report/Technology Assessment No. 222. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2012-00007-I.) AHRQ Publication No. 16-E001-EF. Agency for Healthcare Research and Quality. Rockville, MD: 2016. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
6 What is an electronic health record (EHR)? Health IT; 2013. https://www.healthit.gov/providers-professionals/faqs/what-electronic-health-record-ehr. Accessed on August 11, 2017.
7 Committee on Evaluating Progress of Obesity Prevention Effort, Food and Nutrition Board, Institute of Medicine. Evaluating Obesity Prevention Efforts: A Plan for Measuring Progress. Washington DC: 2013 by the National Academy of Sciences; 2013.
8 Craig P, Cooper C, Gunnell D, . Using natural experiments to evaluate population health interventions: new Medical Research Council guidance. J Epidemiol Community Health. 2012 Dec;66(12):1182–6. doi: 10.1136/jech-2011-200375. PMID: 22577181.22577181
9 Overview of Physical Activity Assessment Tools. National Collaborative on Childhood Obesity Research; 2016. http://www.nccor.org/tools-mruserguides/individual-physical-activity/overview-of-physical-activity-assessment-tools/#summary. Accessed on November 1, 2017.
10 Department of Health and Human Services, Part 1. Overview Information. Department of Health and Human Services. http://grants.nih.gov/grants/guide/pa-files/PA-16-165.html. Accessed on October 24, 2016.
11 Beal V. Wearable Technology. IT Business Edge; 2017. http://www.webopedia.com/TERM/W/wearable_technology.html. Accessed on August 11, 2017.