# Appendix A Acronyms

Table A1 List of acronyms

Acronym | Definition
AHRQ | Agency for Healthcare Research and Quality
APPLE | Alberta Project Promoting Active Living and Healthy Eating in Schools
ATLAS | Active Teen Leaders Avoiding Screen-time
AVHPSP | Annapolis Valley Health Promoting School Project
BMI | Body Mass Index
BRFSS | Behavioral Risk Factor Surveillance System
CDC | Centers for Disease Control and Prevention
CHALK | Choosing Healthy & Active Lifestyles for Kids
CHL | Children’s Healthy Living
CI | Confidence interval
CLASS | Classification of Laws Associated with School Students
CNRA | Child Nutrition and WIC Reauthorization Act
CONSORT | Consolidated Standards of Reporting Trials
CPPW | Communities Putting Prevention to Work
CSHP | Coordinated School Health Program
DC | District of Columbia
DPP | Diabetes Prevention Program
EB4K with Play | Energy Balance for Kids with Play
EHR | Electronic health records
EMR | electronic medical records
EPHPP | Effective Public Health Practice Project
HDI | Human Development Index
HEAL-CHI | Healthy Eating Active Living–Community Health Initiative (HEAL-CHI)^136^
Healthy ONES | The Healthy Options for Nutrition Environments in Schools
HEROES | Healthy, Energetic, Ready, Outstanding, Enthusiastic, Schools
HFH | Healthy Foods Hawaii
HFHF | Healthy Foods, Healthy Families
HIPAA | Health Insurance Portability and Accountability Act
HLCK | Healthy Living Cambridge Kids
HSP | Healthy Schools Program
HUD | Department of Housing and Urban Development
ICAPS | Intervention Centered on Adolescents’ Physical activity and Sedentary behavior
IDEFICS | The Identification and prevention of Diet and lifestyle-induced health EFfects In Children and infantS
IOM | Institute of Medicine
JAWS | Jog and Walk Stars
KNF | Kids N Fitness
KPS | Kearney Public School
KQ | Key Question
MOTMGC | Men on the Move: Growing Communities
MRC | UK Medical Research Council
MSBE | Michigan State Board of Education
M-SPAN | Middle-School Physical Activity and Nutrition
MTO | Moving to Opportunity
NCCOR | The National Collaborative on Childhood Obesity Research
NCHWTF | North Carolina Health and Wellness Trust Fund
NEXT-D | Natural Experiments for Translation in Diabetes
NHANES | National Health and Nutrition Examination Survey
NIH | National Institutes of Health
NPS | National Park Service
NSCH | National Survey of Children’s Health
P2P | Pathways to Prevention Program
PA | Physical activity
PACE | Partnership for an Active Community Environment
PCORI | The Patient Centered Outcomes Research Institute
PCORNet | The National Patient-Centered Clinical Research Network
PICOTS | Populations, Interventions, Comparators, Outcomes, Timing, Setting
POD | Preventing Obesity by Design
RCT | Randomized Controlled Trial
ROBINS-I | The Risk Of Bias In Non-randomized Studies – of Interventions
SNAP | Supplemental Nutrition Assistance Program
SNPI | School Nutrition Policy Initiative
SOPARC | System for observing play and recreation in communities
SOPLAY | System for observing play and leisure activity in youth
SPARK | Sports, Play, and Active Recreation for Kids
SRDR | Systematic Review Data Repository
SRTS | Safe Routes to School
SSB | Sugar sweetened beverages
TEP | Technical expert panel
TFN | Texas Fitness Now
UK | United Kingdom
US | United States
WIC | Women, Infants, and Children
YRBSS | Youth Risk Behavior Surveillance System