# Results

In what follows, we begin by describing the results of our literature searches. We then provide a brief overview description of the included studies. The remainder of the chapter is organized by Key Question (KQ). Under each of the three KQs, we begin by listing the key points of the findings, followed by a brief description of included studies, a detailed synthesis of the evidence, and a final discussion of the results in sections on “Findings in Relation to What Is Known” to provide context for the reader. Within KQ 2, the detailed syntheses are organized first by treatment comparison and then by outcome. We conducted quantitative syntheses where possible, as described in the Methods chapter. For a list of the abbreviations, please refer to the end of the report.

## Results of Literature Searches

Figure 2 depicts the flow of articles through the literature search and screening process. Searches of PubMed^®^, Embase^®^, PsycINFO^®^, and the Cochrane Database of Systematic Reviews yielded 10,742 unique citations. Manual searching of gray literature databases and bibliographies of key articles or referral by investigators identified 21 additional citations, for a total of 10,763 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 1,263 full-text articles were retrieved and screened. Of these, 1,160 were excluded at the full-text screening stage, leaving 103 articles for data abstraction. These 103 articles described 90 unique studies. The relationship of studies to the review questions is as follows: 21 studies relevant to KQ 1, 69 studies relevant to KQ 2, 0 studies relevant to KQ 3.

Figure 2 Literature flow diagram

KQ=Key Question

Figure 2. Literature flow diagram. This figure depicts the flow of articles through the literature search and screening process. Searches of PubMed®, Embase®, PsycINFO®, and the Cochrane Database of Systematic Reviews yielded 10,742 unique citations. Manual searching of gray literature databases and bibliographies of key articles or referral by investigators identified 22 additional citations, for a total of 10,764 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 1,263 full-text articles were retrieved and screened. Of these, 1,160 were excluded at the full-text screening stage, leaving 103 articles for data abstraction. These 103 articles described 90 unique studies. The relationship of studies to the review questions is as follows: 21 studies relevant to KQ 1, 69 studies relevant to KQ 2, 0 studies relevant to KQ 3.

Appendix C provides a detailed listing of included articles. Appendix D provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion. Appendix E provides a “study key” table listing the primary and companion publications for the 90 included studies.

## Description of Included Studies: Overview

Overall, we included 103 articles representing 90 studies: 21 studies were relevant to KQ 1, 69 studies to KQ 2, and 0 studies to KQ 3. Studies were conducted wholly or partly in continental Europe or the United Kingdom (UK) (35 studies, 38%), the United States or Canada (23 studies, 25%), the Middle East (13 studies, 14%), Asia (12 studies, 13%), Latin America (3 studies, 3%), Australia/New Zealand (NZ) (3 studies, 3%), both in the United States and UK/Europe (2 studies, 2%), both in UK/Europe and Australia/NZ (1 study, 1%), and location not reported (1 study, 1%). Further details on the studies included for each KQ are provided in the relevant results sections below and in Appendixes F and G.

Note that our 90 included studies focused on individuals of varying age. To help the reader, we have categorized the included articles as (1) those that targeted children 6 years of age and under, (2) those that targeted children aged 7 through 17, and (3) those that included children of all ages through 17 years. Table 5 lists all included studies by these categorizations, and then throughout the results tables we indicate which age categories the specific studies addressed.

Table 5 Ages of individuals represented in included ADHD studies

KQ | Age Category of Included Participants | Studies
KQ 1 | Ages 6 and under | Bunte, 2013^86^ Thorell, 2010^87^
KQ 1 | Ages 7 through 17 | Berger, 2010^88^ Bloch, 2012^89^ dosReis, 2010^90^ Ferrin, 2012^91^ Kim, 2015^92^ Kim, 2015^93^ Klenberg, 2010^94^ Liechti, 2013^95^ Markovska-Simoska, 2016^96^ Martin-Martinez, 2012^97^ Ogrim, 2012^98^ Ohan, 2011^99^ Park, 2016^100^ Soliva, 2010^101^ Zelnik, 2012^102^
KQ 1 | All ages through 17 | Carballo, 2014^103^ Castro-Cabrera, 2010^104^ Caudal, 2011^105^ Gonzalez, 2013^106^
KQ 2 | Ages 6 and under | Abikoff, 2015^107^
KQ 2 | Ages 7 through 17 | Abikoff, 2013^108^ Anand, 2016^109^ Arcieri, 2012^110^ Arnold, 2011^111^ Bai, 2015^112^ Banaschewski, 2014^113^ Barragan, 2014^114^ Beck, 2010^115^ Bink, 2015^116^ Boyer, 2015^117^ Cetin, 2015^118^ Chacko, 2014^119^ Clemow, 2015^120^ Cortese, 2015^121^ Dovis, 2015^122^ Didoni, 2011^123^ Duric, 2012^124^ Dutta, 2012^125^ Egeland, 2013^126^ Ercan, 2014^127^ Evans, 2016^128^ Ferrin, 2016^129^ Findling, 2010^130^ Gelade, 2016^131^ Gevensleben, 2009^132^ Gustafsson, 2010^133^ Hahn-Markowitz, 2016^134^ Hammerness, 2012^135^ Hariri, 2012^136^ Hong, 2015^137^ Huang, 2015^138^ Johnson, 2009^139^ Katz, 2010^140^ Li, 2011^141^ Manor, 2012^142^ Milte, 2012^143^ Mohammadpour, 2016^144^ Mohammadi, 2012^145^ Molina, 2009^146^ Moreno-Garcia, 2015^147^ Newcorn, 2016^148^ Oberai, 2013^149^ Ostberg, 2012^150^ Panei, 2010^151^ Pfiffner, 2014^152^ Power, 2012^153^ Raz, 2009^154^ Salehi, 2010^155^ Sallee, 2009^156^ Sayer, 2016^157^ Shakibaei, 2015^158^ Sibley, 2016^159^ Steiner, 2014^160^ Storebo, 2012^161^ Trzepacz, 2011^162^ van der Donk, 2015^163^ Vidal, 2015^164^ Widenhorn-Muller, 2014^165^ Zhang, 2010^166^
KQ 2 | All ages through 17 | Chacko, 2009^167^ Ferrin, 2014^168^ Hiscock, 2015^169^ Mautone, 2012^170^ Myers, 2015^171^ Pelsser, 2011^172^ Tobaiqy, 2011^173^ van Dongen-Boomsma, 2014^174^ Webster-Stratton, 2011^175^

ADHD=attention deficit hyperactivity disorder; KQ=Key Question

We searched the ClinicalTrials.gov study registry as a mechanism for ascertaining publication bias by identifying studies that have been completed but are as yet unpublished. We acknowledge that this is not an exhaustive strategy, as several other registries also exist with differing geographical focus and varying degrees of overlap in their trial listings; however, in the opinion of the investigators, the widely used, U.S.-based ClinicalTrials.gov registry provided the most relevant information to the populations and interventions of interest in this review. Our search yielded 348 records of completed trials in the ClinicalTrials.gov registry. Manual review identified 51 of the records from ClinicalTrials.gov as potentially relevant to this review. Of those 51 records, we were not able to identify publications for 7 studies that had expected completion dates 3 years or more prior to our search. Of the 43 studies for which we could identify publications, all were considered potentially relevant to KQ 2. However, all publications had been previously identified in our PubMed, Embase, PsycINFO, and the Cochrane Database of Systematic Reviews searches. No novel publications were identified from our clinical trial registry searches.

Comparisons assessed in the 7 studies that did not have publications were pharmacologic versus pharmacologic (3 studies^176–178^), pharmacologic versus placebo (4 studies^176, 179–181^), and nonpharmacologic versus placebo (1 study^182^). One study contained three different arms evaluating both pharmacologic versus pharmacologic and pharmacologic versus placebo comparisons. We did identify trial results posted online for one study comparing lisdexamfetamine dimesylate versus methylphenidate hydrochloride versus placebo, and we also identified a press release for another study comparing a d-amphetamine transdermal system versus a placebo patch, but no corresponding peer-reviewed articles were found. These 7 studies if completed would add 1,357 patients to our analysis. The included studies in KQ 2 represent evidence from 14,737 patients and so although this is a substantial evidence base the inclusion of an additional 1,357 patients would increase by approximately 9 percent. Given the range of interventions studied and that 4 of them included placebo as a comparator of interest, we do not believe that the 7 “missing” trials are likely to have had a meaningful impact on our review’s results. Because of the relatively low proportion of unpublished studies identified through our ClinicalTrials.gov registry analysis, we do not believe these findings indicate significant publication bias in the evidence base that would impact our overall conclusions.

## Key Question 1 ADHD Diagnosis

KQ 1 examined the comparative diagnostic accuracy of approaches that can be used in the primary care practice setting or specialty clinic to initially diagnose attention deficit hyperactivity disorder (ADHD). KQ 1a focuses on the comparative diagnostic accuracy of approaches for diagnosing ADHD among individuals younger than 7 years of age. KQ 1b examines the comparative diagnostic accuracy of electroencephalography (EEG), imaging, or assessment of executive function that can be used to diagnose ADHD among individuals aged 7 through 17. KQ 1c focuses on how the comparative diagnostic accuracy of these approaches varies by clinical setting or patient subgroup including age, sex, or other risk factors associated with ADHD. KQ 1d examines the adverse effects associated with being labeled correctly or incorrectly as having ADHD. This KQ was not addressed in the prior reports.

To help the reader, Table 6 summarizes the available tools for individuals across the age spectrum and provides details on the domains assessed, the methods used for assessment, scoring methods, and interpretation. Tools are listed within categories of interviews, rating scales, and continuous performance tests.

Table 6 Description of available tools for ADHD assessment

Category | Tool | Domains Assessed | Method | Scoring | Interpretation
Interviews
| Standard clinical interview | ADHD diagnosis according to DSM-IV or DSM-5 criteria | Parent and/or child interview | NA | Diagnostic interview that determines whether an individual has ADHD.
| K-SADS (Kiddie SADS) | ADHD diagnosis according to DSM-IV or DSM-5 criteria | Semi-structured diagnostic interview with parent and child | Items rated on a 3-point scale for severity (not present, subthreshold, and threshold—which combines both moderate and severe presentations). Parent, child, and summary ratings are made. | A diagnostic algorithm that includes all DSM criteria for ADHD. Results of the semi-structured interview indicate whether the individual has ADHD.
| DISC/DISC IV (Diagnostic Interview Schedule for Children) | ADHD diagnosis according to DSM-IV criteria | Structured diagnostic interview with parent and/or child | Items rated as yes, no, somewhat or sometimes | A diagnostic algorithm that includes the DSM criteria for ADHD. Results of the diagnostic interview indicate whether the individual has ADHD.
Rating Scales
| NICHQ (National Institute for Children’s Health Quality) Vanderbilt Assessment Scale | - ADHD Predominantly Inattentive; - ADHD Predominantly Hyperactive/Impulsive; - ADHD Combined; - Oppositional Defiant Disorder; - Conduct Disorder; - Anxiety/Depression | - Parent questionnaire; - Teacher questionnaire | Symptom Questions; - Rated based on frequency; - 0–3 scale (never, occasionally, often, very often); - Number of symptoms endorsed at a 2 (often) or 3 (very often) is summed for each domain; Performance Questions; - Rated based on problem severity; - 0–5 scale (excellent, above average, average, somewhat of a problem, problematic) | - A positive screen indicates the need for further evaluation; - The screening measure is positive if both of the following are met for a given domain:; - Specific number of Symptom Questions are rated 2 or 3; - At least one Performance Question is rated 4 or 5
| Conners Rating Scales; - CPRS; - CTRS; - CRS; - Conners 3 | Note: Subscale names vary slightly between versions of the Conners Rating Scales, but include: ADHD-related scales; - Inattention; - Hyperactivity/Impulsivity; - Learning Problems; - Executive Functioning; - DSM Symptoms Scales; - ADHD Index; - Conners Global Index; Behavioral/emotional scales; - Defiance/Aggression; - Peer Relations/Social Problems; - Family Relations; - Oppositional Defiant Disorder; - Conduct Disorder; - Cognitive Problems; - Anxious-Shy; - Perfectionism; - Psychosomatic | - Parent questionnaire; - Teacher questionnaire; - Adolescent questionnaire | - Rated based on how true the question is for the child; - 0–3 (not true at all, just a little true, pretty much true, very much true). | - Raw scores for each scale are converted to T scores (mean=50, SD=10) based on a normative sample; - Higher scores indicated increased clinical concern; - Interpretation guidelines indicate that scores ≥ 60 are above average
| SNAP-IV (Swanson, Nolan and Pelham Revision) | - ADHD Predominantly Inattentive; - ADHD Predominantly Hyperactive/Impulsive; - ADHD Combined | - Parent questionnaire; - Teacher questionnaire | - Rated based on frequency; - 0–3 scale (not at all, just a little, quite a bit, very much) | - Scores can be interpreted in two different ways:; 1. Sum of items for each of the three subscales, with high score indicating more symptoms.; 2. Average rating per item for each of the three subscales. This rating is compared to the parent/teacher 5% cut off and a higher score indicates more symptoms.
| DBDRS (Disruptive Behavior Disorder Rating Scale ) | - ADHD Predominantly Inattentive; - ADHD Predominantly Hyperactive/Impulsive; - ADHD Combined; - Oppositional Defiant Disorder; - Conduct Disorder | - Parent questionnaire; - Teacher questionnaire | - Rated based on frequency; - 4 point scale (not at all, just a little, pretty much, and very much) | - Scales scores are computed by summing the items in each domain.; - Scores were considered to be in the clinical range for ADHD if they are between the 95th to 100th percentile.
| ADHD-RS (ADHD Rating Scale) | - ADHD Predominantly Inattentive; - ADHD Predominantly Hyperactive/Impulsive; - ADHD Combined | - Parent questionnaire; - Teacher questionnaire | - Rated based on frequency; - 0–3 (does not experience the symptom at all … symptom very often) | - Scores are calculated by summing the items in each domain and the total items.
| SDQ (Strengths and Difficulties Questionnaire) | - Emotional symptoms; - Conduct problems; - Hyperactivity/inattention; - Peer relationship problems; - Prosocial behavior; - Total difficulties | - Parent questionnaire; - Teacher questionnaire | - Rated based on how true the question is for the child; - 0–2 (not true, somewhat true, certainly true); - Some items are reverse coded. | - Higher scores indicate more concerns in a given area.; - Raw scores can be compared to cut-points derived from a typical population.
| BRIEF (Behavior Rating Inventory of Executive Function) | - Behavioral Regulation Index (three scales); - Metacognition Index (five scales); - Global Executive Composite | - Parent questionnaire; - Teacher questionnaire | - Rated based on frequency; - 3-point scale (never, sometimes often) | - Raw scores are converted to T scores (mean=50; SD=10) and percentiles based on a normative sample.; - Higher scores indicate more problems relative age-matched peers.
| CHEXI (Childhood Executive Functioning Inventory) | - Inhibition (inhibition and regulation; - Working Memory (working memory and planning) | - Parent questionnaire; - Teacher questionnaire | - Rated based on how true the question is for the child; - 0–5 point (definitely not true, not true, partially true, true, definitely true) | - Subscale scores are calculated by computing the mean score for items in each scale.; - Higher scores are indicative of more severe symptoms.
| ATTEX (Attention and Executive Function Rating Inventory) | - Distractibility; - Impulsivity; - Motor hyperactivity; - Directing attention; - Sustaining attention; - Shifting attention; - Initiative; - Planning; - Execution of action; - Evaluation; - Total score | - Teacher questionnaire | - Rated based on severity; - 3-point scale (not a problem, sometimes a problem, often a problem) | - Subscale scores are calculated by computing the mean score for items in each scale.; - A Total Score is calculated by summing all of the scale scores.; - Higher scores indicate greater severity (i.e., the behavior is more often a problems).
Continuous Performance Tests
| Conners CPT (Continuous Performance Test) | - Attention; - Impulsivity; - Sustained Attention; - Vigilance | - Computerized test | - Responses to a target and nontarget | - Raw and standardized scores are calculated using an algorithm for each domain.; - T scores and percentiles are provided, with higher scores indicating more problems in a given area.
| IVA CPT (Integrated Visual and Auditory Continuous Performance Test) | - Auditory Response Control; - Visual Response Control; - Auditory Attention; - Visual Attention; - Auditory Sustained Attention; - Visual sustained Attention | - Computerized test | - Responses to the target (visual or auditory) and to the nontarget (visual or auditory) | - Visual and Auditory domain scores are calculated for a total of 12 quotients.; - Omission and commission scores are generated, with more omission errors indicating greater distraction and more commission errors indicating greater impulsivity.; - Hyperactivity-impulsiveness and attention deficit scales are calculated from the omission and commission errors, each comprising 3 visual and 3 auditory quotients.
| TOVA (Test of Variables of Attention) | - Attention; - Inhibitory control | - Computerized test | - Responses to the target (correct) and responses to the nontarget (incorrect) | - Errors of omission (not responding to the target) yield a measure of inattention.; - Errors of commission (responding to a nontarget) yield a measure of impulsivity.
| CANTAB (Cambridge Neuro-psychological Test Automated Battery)^a^ | - General memory and learning, with subtests including:; - Working memory; - Executive functioning; - Visual memory; - Attention; - Reaction time; - Decision making; - Response control | - Computerized test | - Scoring varies by domain and includes scores such as percent correct, number of errors, time to complete, response latency | - Interpretation varies depending on the outcome measures (e.g., higher number of errors indicates more impairment; lower response latency indicates less impairment).

a CANTAB description from personal communication with Cambridge Cognition Ltd. (January 2017).

Abbreviations: ADHD=attention deficit hyperactivity disorder; CPRS=Conners Parent Rating Scale; CTRS=Conners Teacher Rating Scale; DSM=Diagnostic and Statistical Manual of Mental Disorders

### Description of Included Studies

For KQ 1, we identified 22 articles^86–106, 183^ representing 21 studies, 19 of which examined the comparative diagnostic accuracy of approaches used to diagnose ADHD, and 2 of which evaluated adverse effects of being labeled with ADHD. One study was described in more than one publication; Appendix E provides a key to primary and companion articles. Primary and companion papers are cited together in the text and tables that follow.

All 19 studies examining diagnostic accuracy were observational in design and represented a total of 4,339 enrolled patients. The 2 studies examining the adverse effects of ADHD labeling were observational in design and represented a total of 104 enrolled patients. Details of the study characteristics of the included studies are in Appendix F. Appendix G provides an overview of the included studies.

### Key Points

- Among executive function tests, Attention and Executive Function Rating Inventory (ATTEX) and Childhood Executive Function Inventory (CHEXI) performed better than Cambridge Neuropsychological Testing Automated Battery (CANTAB) for individuals aged 7–17 (strength of evidence [SOE]=low).
- This systematic evidence review identified limited studies with variable and inconsistent findings for diagnostic accuracy for all other diagnostics tools evaluated, including imagining and EEG-based tests (SOE=insufficient).
- Insufficient evidence was found regarding labeling or stigma of children with ADHD.

### Detailed Synthesis—Diagnosis

#### Diagnostic Comparative Studies

Across the 19 diagnostic comparative studies, 14 different assessment tools were evaluated, including electroencephalography (EEG), integrated visual and auditory computerized performance test (IVA-CPT), continuous performance function tests (CPFT), event-related potentials (ERP), magnetic resonance imaging (MRI) of caudate body volume, Test of Variables of Attention (TOVA), CANTAB, ATTEX, CHEXI, electro interstitial scans (EIS), Disruptive Behavior-Diagnostic Observation Schedule (DB-DOS), neurological subtle signs (NSS), Kiddie-Disruptive Behavior Disorder Schedule (K-DBDS), and Strengths and Difficulties Questionnaire (SDQ). The diagnostic accuracy of the tools was measured primarily by receiver operator characteristics (ROC) for overall accuracy and area under the curve (AUC), from which sensitivity, specificity, false positives, and false negatives could be derived as shown in Table H-1, which summarizes findings from studies with subjects aged 6 years and younger, and Table H-2, which summarizes findings from studies with older children and adolescents, in Appendix H. The heterogeneity in methods and outcomes of these studies prevented quantitative meta-analysis.

Among the imaging studies, EEG was variable in its accuracy, ranging from 46 percent to 87 percent in five studies.^92, 93, 96, 98, 106^ ERP evaluations yielded consistently higher accuracy scores when conducted independently (91%, the highest imaging accuracy^104^) and in combination with EEG (73%^95^). MRI scans of caudate body volume also had accuracy scores of 84%.^101^ IVA-CPT had 75 percent to 82 percent based on outcomes assessed with omission errors and 68 percent to 85 percent based on outcomes assessed with omission errors.^92, 93, 98^ Other CPTs, such as the TOVA, demonstrated limitations in their ability to correctly identify non-ADHD patients^88, 89, 102^ and subtypes such as inattentive and hyperactive/impulsive.^100^ Among the executive function tests, ATTEX^94^ and CHEXI^87^ performed better with overall accuracy rates of 91 percent to 93 percent, respectively, than the CANTAB,^89^ which had low specificity (low SOE). Biometric devices such as EIS and Actigraphy had high sensitivity (80% to 97%) and specificity (84% to 98%).^97, 105^ Additional approaches to diagnosing ADHD with promising clinical utility included neurological examinations for subtle signs of abnormal functioning (overall accuracy 84%), observational assessments of disruptive behaviors (92% AUC, 87% sensitivity, 79% specificity), and interviews using the K-DBDS (98% AUC, 77% sensitivity, 98% specificity.^86, 91, 183^

Few studies examined whether there are differences in accuracy based on age,^91^ sex,^94^ and ADHD presentation.^86, 94, 100, 103, 183^ Also, there were no studies that compared how approaches to diagnosing ADHD differed by clinical settings. Collectively, a variety of approaches were tested in primary care and specialty clinics. Approaches in primary care clinics (five studies) included imaging, computerized function tests, executive function tests, and standardized questionnaires. Similarly, studies conducted in specialty clinics (13 studies) investigated these same approaches as well as biometric tools and observational assessments.

#### ADHD Labeling/Stigma Studies

Only two studies evaluated the adverse effects associated with being labeled correctly or incorrectly as having ADHD.^90, 99^ These good-quality studies did not address the negative experiences or outcomes of the children with ADHD but rather teachers’ reactions and parents’ concerns regarding ADHD labels for affected youth. Insufficient evidence was found regarding labeling or stigma. This KQ was not addressed with the 2011 review.

### Strength of Evidence—Diagnosis

Tables 7 and 8 summarize the SOE for the KQ 1 findings based on this report’s included studies. The studies evaluated diverse tools and the heterogeneity in their findings and precision led to insufficient SOE for most tools.

Table 7 Strength of evidence for major outcomes—diagnosis

Diagnostic Tool SOE Grade | No. Studies/Design (N Patients) Age Categories | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Findings
EEG and Imaging Insufficient | 5 Obs (259) 7–17, all through 17 | Medium | Direct | Inconsistent | Imprecise | None | EEG demonstrated variability in five studies.^95, 101, 104, 106^ ^96^
EEG, Imaging, and CPT Insufficient | 3 Obs (355) 7–17 | Medium | Direct | Inconsistent | Imprecise | None | EEG demonstrated variability in four studies..^92, 93, 98^
CPT Insufficient | 3 Obs (402) 7–17 | Medium | Direct | Inconsistent | Imprecise | None | CPT demonstrated variability in 3 observational studies.^88, 100, 102^
CPT and executive function Insufficient | 1 Obs (34) 7–17 | Medium | Direct | NA | Imprecise | None | SOE was insufficient because of the sample size of the single observational study available.^89^
Executive function Low | 2 Obs (961) 6 and under, 7–17 | Medium | Direct | Consistent | Precise | None | Among executive function tests, ATTEX and CHEXI performed better than the CANTAB.^87, 94^
Biometric Devices Insufficient | 2 Obs (175) 7–17, all through 17 | Medium | Direct | Inconsistent | Imprecise | None | Biometric devices for EIS and actigraphy demonstrated variability in the 2 studies.^97, 105^
Observational assessment Insufficient | 2 Obs (1,436) 6 and under, 7–17 | Medium | Direct | Inconsistent | Imprecise | None | SOE was insufficient because of variations across the 2 available observational studies.^91, 183^
Standardized questionnaire Insufficient | 2 Obs (774) 6 and under, all through 17 | Medium | Direct | Inconsistent | Imprecise | None | SOE was insufficient because of variations across the 2 available observational studies.^86, 103^

Abbreviations: ATTEX=Attention and Executive Function Rating Inventory; CANTAB=Cambridge Neuropsychological Testing Automated Battery; CHEXI=Childhood Executive Function Inventory; CPT=continuous performance test; EEG=electroencephalography; NA=not applicable; Obs=observational; SOE=strength of evidence

Table 8 Strength of evidence for major outcomes—labeling/stigma

Outcome SOE Grade | No. Studies/Design (N Patients) Age Categories | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Findings
Labeling/Stigma | 2 Obs (104) | Low | Indirect | Consistent | Imprecise | None | SOE was insufficient because the studies did not address the negative experiences or outcomes of the children with ADHD but rather teachers’ reactions and parents’ concerns regarding ADHD labels for affected youth.^90, 99^
Insufficient | 7–17 | Low | Indirect | Consistent | Imprecise | None

Abbreviations: ADHD=attention deficit hyperactivity disorder; Obs=Observational; SOE=strength of evidence

## Key Question 2 ADHD Treatment

KQ 2 examined the comparative safety and effectiveness of pharmacologic and nonpharmacologic treatments for improving outcomes associated with ADHD. KQ 2 also evaluates how these outcomes vary by presentation (inattentive, hyperactive/impulsive, and combined) or other comorbid conditions, and assesses the risk of diversion of pharmacologic treatment. For the purposes of this review, supplements were classified as nonpharmacologic treatments because they are not regulated by the FDA.

### Description of Included Studies

For KQ 2, we identified 81 articles^107–175, 184–195^ representing 69 studies that examined the comparative safety and effectiveness of pharmacologic and nonpharmacologic treatments for the treatment of ADHD. Eleven studies were described in more than one publication; Appendix E provides a key to primary and companion articles. Primary and companion papers are cited together in the text and tables that follow.

Of the 69 included studies, 10 were observational, representing a total of 6,523 enrolled patients.^110, 115, 120, 121, 123, 127, 135, 151, 166, 173^ The 59 remaining studies were randomized controlled trials (RCTs), representing a total of 8,346 enrolled patients. Details of the study characteristics of the included studies are in Appendix F. Appendix G provides an overview of the included studies.

The next sections are organized by treatment comparisons as follows:

1. Pharmacologic versus placebo/usual care
2. Pharmacologic versus pharmacologic
3. Pharmacologic versus nonpharmacologic
4. Nonpharmacologic versus nonpharmacologic/placebo

### Key Point for Pharmacologic Versus Placebo/Usual Care

- There was limited additional evidence concerning FDA-approved ADHD medications compared with placebo or usual care across all outcomes in this updated systematic evidence review (SOE=insufficient).

### Detailed Synthesis—Pharmacologic Versus Placebo/Usual Care

For this comparison, we identified eight articles^113, 130, 135, 146, 148, 162, 166, 192^ representing seven studies that compared an FDA-approved medication for ADHD with placebo or usual care. The study with two publications was the National Institute of Mental Health (NIMH) Collaborative Multisite Multimodal Treatment Study of Children with ADHD (MTA) in which one publication reported academic performance, psychiatric outcomes, and antisocial behavior between treatment arms at 8 years following the 14 months of active treatment,^146^ and the other reported blood pressure and heart rate by initial treatment group assignments over 10 years.^192^ Three of the six studies were conducted exclusively in the United States,^130, 135, 146^ two were conducted in the United States and Europe,^113, 148^ one study was conducted in Asia,^166^ and one was conducted in Europe, Australia, New Zealand, Israel, and South Africa.^162^

Two studies were rated poor quality^113, 166^ and the remaining rated fair quality. Both studies rated as poor quality had incomplete reporting of methods and results along with a high dropout rate. All but two^135, 166^ were multicenter studies, and all of the multicenter studies were classified as RCTs; however, one study randomized subjects to treatment following an initial RCT (withdrawal) to either continue lisdexamfetamine or placebo and assessed effects in the “withdrawal period,”^113^ one study randomized treatment following an open-label study to either extended release guanfacine or placebo and assessed effects in the “withdrawal period,”^148^ and one study (two articles) reported results long after the RCT treatment periods.^146, 192^

Placebo was the comparator in all of the studies except the two observational studies^135, 166^ and the MTA study.^146^ For the findings from the MTA study discussed in this section, only the comparison between the medication arm and community care arm are reported. There were only two treatment arms in all of the RCTs with placebo comparators except for one study in which there were three doses of lisdexamfetamine compared with placebo.^130^ In the MTA study, there were also 4 treatment arms—medication management, behavioral management, combination of medications and behavior management, and community care (usual care). Medication management in MTA included 1-month double-blind titration with methylphenidate for best dose, progressing to an open titration with other drugs, such as d-amphetamine, pemoline, or imipramine if methylphenidate was unsatisfactory.

The two observational studies evaluated longer term outcomes. Methylphenidate (MPH) was the pharmaceutical in both studies, with doses of 0.3 to 0.6 mg/kg per day^166^ and up to 1.5 mg/kg per day.^135^ One study^135^ compared study participants in the treatment group with a naturalistic sample as a control. The goal of that study was to determine if the 24-month use of MPH affected the risk of alcohol and illicit drug outcomes. The other study^166^ also examined long-term (2–4 years) use of MPH and the risk of height and weight gaps or growth deficits.

#### Changes in Standardized Symptom Scores

One fair-quality study presented results of ADHD symptom scores in children with active pharmacologic treatment versus placebo.^130^ Three doses of lisdexamfetamine were compared with placebo. Although no statistical comparisons were made, there was a much smaller proportion of patients receiving placebo when compared with any dose of lisdexamfetamine that had achieved symptomatic remission at 1 month, defined as an ADHD-RS-IV score ≤18 (23.6% placebo, 62.3% lisdexamfetamine 30 mg/day, 67.6% lisdexamfetamine 50 mg/day, and 71.2% lisdexamfetamine 70 mg/day).

A second fair-quality study presented results of ADHD symptom scores in children initially stabilized on extended release guanfacine and then randomized to either continuation of the extended release guanfacine or placebo during a 26-week “withdrawal period.”^148^ The difference in the LS mean of the ADHD-RS-IV total score at the end of the “withdrawal period” for those continuing extended release guanfacine was statistically significantly lower than those who received placebo indicating that the effect of the treatment was better maintained with continuation of extended release guanfacine as compared to placebo (−6.24; 95% confidence interval [CI] −9.01 to −3.48; ES=0.51, p<0.001). These inconsistent and imprecise findings resulted in insufficient SOE.

#### Functional Impairment

One fair-quality study presented results of the Clinical Global Impression-Severity scores in children initially stabilized on extended release guanfacine and then randomized to either continuation of the extended release guanfacine or placebo during a 26 week “withdrawal period.”^148^ The proportion of children with low severity score (score 1 or 2) at the end of the “withdrawal period” was statistically significantly lower in those who continued extended release guanfacine versus placebo in the “withdrawal period” (50% vs. 32.5%, p =.0.001). The SOE was insufficient given findings from this one study with imprecise findings and medium risk of bias.

#### Alcohol Use

One fair-quality study focused on assessing youth self-reported alcohol use using the Drug Use Screen Inventory in children aged 12 to 17 who were mostly male.^135^ The study groups for this observational study conducted in the United States were clinical trial participants receiving open label MPH, nonclinical trial youth receiving MPH or amphetamine per their primary care provider, nonclinical trial youth not receiving any ADHD medications, and youth without ADHD. A lower proportion of clinical trial participants reported alcohol use in the preceding year (10%) than nonclinical trial youth receiving MPH or amphetamine (33%, p=0.008 compared with clinical trial participants) or nonclinical trial youth not receiving any ADHD medications (35%, p=0.002 compared with clinical trial participants). However, it is not clear whether the clinical trial participation or the more rigorous screening for the clinical trial created a selection bias (insufficient SOE).

#### Sexual Development

One fair-quality study focused on sexual development in children initially aged 6 to 15 years who were randomized to atomoxetine versus placebo.^162^ Among 394 patients who were mostly male, no statistically significant differences were seen in median age of puberty (12.6 in atomoxetine [ATX] group and 12.3 in placebo group, p=0.88) or frequency of onset of puberty (26% in ATX group and 26.9% in placebo group p=0.88). However, the mean height change was higher in the placebo group (3.2 inches in ATX group and 4.22 in placebo group, p=0.01). The SOE was insufficient given imprecise evidence from this one study.

#### Peer Relationships

One poor-quality study reported results of the quality of peer relationships on the CHIP-CE PRF subdomain for peer relationships at the end of a 6-week period in which one group had their lisdexamfetamine continued and the other group was switched to placebo.^113^ The effect size was 0.434 (p<0.001) for the lisdexamfetamine group versus placebo, indicating better peer relationships in the lisdexamfetamine group than placebo. The SOE was insufficient given evidence from this one study with incomplete reporting of both methods and outcomes, along with high dropout rates.

#### Risk Avoidance

One poor-quality study reported results of risk avoidance on the Child and Health Illness Profile Child Edition, Parent Report Form (CHIP-CE PRF) subdomain risk avoidance at the end of a 6-week period in which one group had their lisdexamfetamine continued and the other group was switched to placebo.^113^ The effect size was 0.613 (p<0.01) for the lisdexamfetamine group versus placebo, indicating greater risk avoidance in the lisdexamfetamine group than placebo. Again limitations of the study, combined with imprecise findings led to an insufficient SOE.

#### Academic Performance

The four-arm MTA study reported results of academic performance at 8 years, finding no statistically significant treatment effects identified for reading, math, or GPA at 8 years.^146, 192^ Insufficient evidence is available to know whether this is due to a lack of long-term treatment benefit or reflects the need for more intensive care for the subjects after completion of the MTA study.

#### Antisocial Behavior, Accidents, and Psychiatric Illness

The four-arm MTA study found no statistically significant treatment effects on incarceration, aggression, or motor vehicle accidents at 8 years.^146, 192^ There was a statistically significant treatment effect with anxiety at 8 years (14.9% medication management, 16.7% behavioral management, 18.3% combination, and 19.7% placebo; p value for treatment effect=0.0217). The SOE was insufficient as these findings were based on a stepped approach and it was unclear which specific medications subjects received.

#### Adverse Effects

In one study, selected adverse effects of ATX versus placebo were reported.^162^ There was a higher rate of increased appetite (7.1% vs 1.4%, p=0.006) and gastrointestinal symptoms (8.2% vs. 2.7%, p=0.046) in patients receiving ATX versus placebo (insufficient SOE for both others). Findings from this same study and the one poor-quality observational study^166^ indicate small significant reductions in height and weight among the MPH groups and higher rates of alcohol or drug use during the past year. Both studies compared ADHD participants with non-ADHD participants. The SOE was insufficient given the findings were the large loss to followup and potential risk of bias.

### Findings in Relation to What Is Already Known—Pharmacologic Versus Placebo/Usual Care

In the 2011 report,^4^ 13 short-term studies compared MPH with placebo (one also compared mixed amphetamine salts [MAS] with placebo) in children under 6 years of age; 9 longer term studies compared pharmacologic agents (4 MPH, 2 ATX, 1 amphetamine or MAS, and 2 any stimulant) with placebo. The studies in children under 6 years of age were relatively small and thus most of the conclusions are based on a single larger RCT of good quality, the Preschool ADHD Treatment Study (PATS),^196^ indicating that for children without comorbidities, MPH was very effective (SOE=low).

In people 6 years of age and older, the 2011 report did not focus on comparative efficacy or safety of pharmacologic drugs compared with placebo. Therefore, no definitive conclusions were made in that report for any ADHD drug compared with placebo.

Our update evaluates one additional poor-quality study, observational in design, by Zhang et al.^166^ that specifically looked at the long-term outcomes of height and weight from MPH use. Findings from that study indicate small but significant reductions in height and weight among the MPH groups compared with non-ADHD participants. Given the large rate of loss to follow up within this study and inadequate reporting of methods and results the SOE was insufficient.

This updated systematic review—although focused on assessing the comparative efficacy and safety of FDA approved ADHD medications versus placebo—was likewise unable to make definitive conclusions given the small number of studies during the current time period and the limited quality of those studies. There is insufficient overlap in study design and outcomes between the findings in this updated systematic review and the 2011 report to qualitatively improve the certainty regarding the benefits and harms of treatment beyond the individual reviews’ findings.

### Strength of Evidence—Pharmacologic Versus Placebo/Usual Care

Table 9 summarizes the SOE for comparisons between pharmacologic and placebo/usual care treatments based on this report’s included studies. For most outcomes there was only one either low- or fair-quality study exploring the outcome of interest with imprecise findings and so the evidence was given an insufficient SOE grade.

Table 9 Strength of evidence for major outcomes—comparisons between pharmacologic and placebo/usual care treatments

Outcome SOE Grade | No. Studies/Design (N Patients) Age Category | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Findings
Major outcomes
Changes in standardized symptom scores Insufficient | 2 RCTs (359) 7–17 | Medium | Direct | Inconsistent | Imprecise | Unclear | SOE was insufficient because of inconsistent and imprecise findings within 2 studies with medium risk of bias.^130, 148^
Functional Impairment Insufficient | 1 RCT (219) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was insufficient because of only one study was included with medium risk of bias and imprecise findings.^148^
Substance abuse Insufficient | 1 Obs (211) 7–17 | Medium | Direct | NA | Imprecise | None | SOE was insufficient given medium risk of bias within one observational study.^135^
Sexual Development Insufficient | 1 RCT (394) 7–17 | Medium | Direct | NA | Imprecise | None | SOE was insufficient because only one study was included with medium risk of bias and imprecise findings^162^
Quality of peer relationships Insufficient | 1 RCT (Unclear) 7–17 | High | Direct | NA | Imprecise | Unclear | SOE was insufficient given evidence from one low-quality study with imprecise findings.^113^
Risk-taking behaviors Insufficient | 1 RCT (Unclear) 7–17 | High | Direct | NA | Imprecise | Unclear | SOE was insufficient given evidence from one low-quality study with imprecise findings.^113^
Academic performance Insufficient | 1 RCT (436) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was insufficient because medication management was based on a stepped approach and it was unclear which specific medications subjects received.^146, 192^
Aggression Insufficient | 1 RCT (436) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was insufficient because medication management was based on a stepped approach and it was unclear which specific medications subjects received.^146, 192^
Incarceration Insufficient | 1 RCT (436) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was insufficient because medication management was based on a stepped approach and it was unclear which specific medications subjects received.^146, 192^.
Motor vehicle collisions Insufficient | 1 RCT (436) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was insufficient because medication management was based on a stepped approach and it was unclear which specific medications subjects received.^146, 192^
Depression or anxiety Insufficient | 1 RCT (436) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was insufficient because medication management was based on a stepped approach and it was unclear which specific medications subjects received.^146, 192^
Changes in appetite Insufficient | 1 RCT (394) 7–17 | Medium | Direct | NA | Imprecise | None | SOE was insufficient because only one study was included with medium risk of bias and imprecise findings^162^
Elevated blood pressure Insufficient | 1 RCT (493) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was insufficient because medication management was based on a stepped approach and it was unclear which specific medications subjects received.^146, 192^
Gastrointestinal symptoms Insufficient | 1 RCT (394) 7–17 | Medium | Direct | NA | Imprecise | None | SOE was insufficient because of only one study was included with medium risk of bias and imprecise findings.^162^
Growth suppression Insufficient | 1 RCT, 1 Obs (569) 7–17 | High | Direct | NA | Imprecise | None | SOE was insufficient because of high risk of bias given high loss to follow up combined with imprecise findings.^162, 166^
Increased heart rate Insufficient | 1 RCT (507) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was insufficient because medication management was based on a stepped approach and it was unclear which specific medications subjects received.^146, 192^

Abbreviations: NA=not applicable; Obs=observational; RCT=randomized controlled trial; SOE=strength of evidence

### Key Points for Pharmacologic Versus Pharmacologic

- Based on evidence from 3 observational studies identified in this systematic evidence review, the proportion of patients reporting gastrointestinal (GI) effects was slightly higher for ATX than MPH (SOE=low).
- Since the 2011 report which described the benefit of psychostimulant therapy for up to 24 months, little additional evidence has been generated for comparing safety and efficacy of select FDA-approved medications for treatment of ADHD and SOE was insufficient for all other outcomes.

### Detailed Synthesis—Pharmacologic Versus Pharmacologic

For this comparison, we identified nine studies.^110, 118, 120, 121, 123, 151, 156, 157, 173^ Of these, seven were multisite studies,^110, 120, 121, 123, 151, 156, 173^ and two were a single site.^118, 157^ Two studies were RCTs.^118, 157^ Among the seven observational studies, four analyzed data from the Italian National ADHD Registry—three from a whole region^110, 121, 151^ and one from selected sites in a specific region.^123^ Government funding was reported for five studies,^110, 123, 151, 157, 173^ industry funding for two studies,^120, 156^ and unknown funding for two studies.^118, 121^

Treatments compared in five of the studies were ATX versus MPH.^110, 118, 121, 123, 151^ One study compared extended-release guanfacine monotherapy with extended release guanfacine plus either amphetamine or MPH,^156^ one assessed ATX monotherapy compared with ATX combined with any other ADHD medication,^120^, one was a survey collecting patient-reported adverse events from any ADHD medication,^173^ and one study compared cardiovascular effects of immediate release guanfacine, extended release dexmethylphenidate, or their combination.^157^

Of the nine studies, two reported results using one of the selected ADHD symptom scores, the Conner Rating Scale-Parent^118^ and the ADHD Rating Scale.^156^ One study reported results from one of the selected functional impairment tests, the Clinical Global Impression.^120^ Of the nine studies, seven only reported adverse events of interest for this systematic review.^110, 121, 123, 151, 156, 157, 173^

#### Changes in Standardized Symptom Scores

Two studies reported results of ADHD symptom scores.^118, 156^ One study was an RCT conducted in a single site in Turkey in which children between the ages of 7 and 16 were randomly assigned to receive ATX (59 evaluable) or osmotic release oral system MPH (OROS-MPH) (61 evaluable).^118^ The Conners Comprehensive Behavior Rating Scale-Teacher was used to assess and compare changes on the hyperactive, inattentive, and behavior subscales from baseline to 6 months and to compare the proportion of children achieving at least a 40-percent reduction in the hyperactive, inattentive, and behavior subscales at 6 months. There were no statistically significant differences between the children taking ATX and those taking OROS-MPH in any of these measures. This study was rated as fair quality.

The second study was an observational study enrolling children from two prior RCTs conducted in the United States evaluating extended-release guanfacine (one of which permitted use of amphetamine or MPH with the extended-release guanfacine).^156^ In this observational extension study, children aged 6 to 17 at initiation received one of four doses of extended-release guanfacine monotherapy (n=206) or any dose of extended-release guanfacine in combination with amphetamine or MPH as the combination group (n=53). The ADHD Rating Scale was used to assess ADHD symptoms at various time points. The change in score within each treatment arm (monotherapy or combination therapy) from baseline to last assessment (time varied up to 24 months) was determined, but treatment arms were not compared. There was a statistically significant decrease in mean score in each arm; −20.1 (± 13.5) for monotherapy and −16.1 (± 11) for combination therapy (both p < 0.001). This study was rated as poor quality given several potential risks of bias including lack of allocation concealment and blinding. In addition participants were subjects from prior studies who were titrated to tolerated dose of guanfacine then assessed for changes in ADHD symptoms increasing potential bias.

The SOE was insufficient given the heterogeneity between the symptom scores, inconsistency in findings, and the potential high risk of bias.

#### Functional Impairment Scores

Only one study presented results using a selected functional impairment tool.^120^ This study was an industry-funded, observational study conducted in two U.S. sites. Chart-abstracted data were used to compare least-square means of the Clinical Global Impression scale assessed at least 50 days after the start of pharmacologic therapy in children aged 6 to 17 receiving ATX monotherapy (n=37) compared with children receiving ATX combination therapy (combined with any other ADHD medication) (n=34). The statistical model was adjusted using propensity scores. No statistically significant difference in least-square mean Clinical Global Impressions Score was found between the treatment groups (p=0.4072). This study was rated as poor quality given its retrospective nature, lack of power, and issues with reporting of its methods and outcomes (SOE=insufficient).

#### Adverse Events

Seven studies presented adverse events from ADHD pharmacologic therapies.^110, 121, 123, 151, 156, 157, 173^ One fair-quality study presented results from a single survey of the parents of 578 children aged 3 to 16 conducted in the UK to ascertain recalled adverse drug reactions to any ADHD medication.^173^ Among 200 completed surveys, 80 percent were from children taking MPH alone or in combination. Because the number of patients exposed to each drug or drug combination was not reported, it is difficult to draw any conclusions from these results.

Four studies reporting adverse effects were observational studies comparing ATX with MPH.^110, 121, 123, 151^ All of these used data from the Italian National ADHD Registry—three in whole^110, 121, 151^ and one from selected sites in a specific region.^123^ Thus, it is not possible to determine the total number of unique patients, as patients may have been included in more than one study. Of these four studies, one poor-quality study focused on electrocardiogram (ECG), blood pressure, and heart rate changes only.^110^ In this study, there was a higher risk of having at least one altered ECG (right bundle branch block [RBBB], sinus bradycardia, sinus tachycardia, increased QTc, and/or atrioventricular [AV] block) at 6 months (relative risk [RR] 1.29; 95% CI 0.52 to 3.21) and 12 months (RR 2.41; 95% CI 1.04 to 5.60) in patients receiving MPH versus ATX, although the increased risk at 6 months was not statistically significant. Systolic blood pressure, diastolic blood pressure, and heart rate were not compared by treatment arms but rather by changes at 6, 12, and 24 months. The only statistically significant change in patients taking MPH was an increase in heart rate at 6 months. The only statistically significant changes in patients taking ATX were an increase in heart rate as measured at 6 and 12 months and an increase in diastolic blood pressure as measured at 6 months. Given the short time frame for this study and therefore lack of patients with events, there is concern that this study was not representative.

The other three studies using the Italian National ADHD Registry and comparing ATX with MPH reported on numerous adverse events (Table H-3 in Appendix H). Overall, gastrointestinal side effects or decreased appetite were the most commonly reported problems. In one of these studies after controlling for presence of comorbid psychiatric conditions, there was a statistically higher incidence rate ratio for gastrointestinal side effects (4.56; 95% CI 2 to 10.43), cardiovascular side effects (3.43; 95% CI 1.21 to 9.76), and neuropsychiatric side effects (2.54; 95% CI 1.34 to 4.74) for ATX versus MPH.^121^ In another, there was a statistically significant greater risk of adverse reactions to ATX versus MPH (RR 3.57; 95% CI 1.92 to 6.64).^151^ These studies were rated as fair to good quality.

A sixth study reporting adverse effects was a poor-quality RCT comparing extended-release guanfacine monotherapy versus combination therapy with amphetamine or MPH.^156^ The rates of selected adverse events are presented in Table H-4 in Appendix H. Among the adverse events listed, somnolence and headache were the most common but were similar between the different groups.

The last study reporting only side effects of interest was a single-center RCT of good quality in which heart rate, systolic blood pressure, and diastolic blood pressure were reported over a 12 month open label follow-up period to a three armed RCT of immediate release guanfacine, extended release dexmethylphenidate, or the combination.^157^ The number of patients who continued in the follow-up period was not reported. There was no statistically significant difference in heart rate over the 12 months between groups (p=0.09), but there were statistically significant differences between groups in systolic and diastolic blood pressure (p=0.0005 and p=0.01, respectively) with both systolic and diastolic blood pressure being higher for those who received extended release dexmethylphenidate as compared to the other two treatment arms.

The SOE for a slight increase in gastrointestinal symptoms for patients on ATX compared with MPH was low. For all other adverse effects the SOE was insufficient.

### Findings in Relation to What Is Already Known—Pharmacologic Versus Pharmacologic

The 2011 report^4^ included comparisons of pharmacologic agents (MPH, DEX, MAS, ATX, and extended release guanfacine) in children under 6 years of age with ADHD or disruptive behavior disorder as part of KQ 1 and in people 6 years of age and older (including adults) with ADHD in KQ 2. In that systematic review, there were relatively few studies that directly compared pharmacologic agents relative to the number of studies that compared medications to placebo, nonpharmacologic assessment, and noncomparative studies. In children under 6 years of age, no studies directly compared pharmacologic agents. Our review did not specifically focus on this population of patients; however, children as young as 3 years of age were included in studies reported on adverse events associated with pharmacologic agents in comparative assessments.

In people aged 6 years and older, there were nine comparative studies of pharmacologic agents in the 2011 report; however, that report was focused on ascertaining only longer-term efficacy and safety. Because of the small number of comparative studies of pharmacologic agents, no specific conclusions were made regarding the comparative efficacy or safety of the included pharmacologic agents. The included studies spanned the following comparisons: one study compared efficacy in people receiving MPH compared with pemoline;^197^ but pemoline is not a pharmacologic agent of interest in this updated review as it has been removed from the US market. One other study compared extended-release guanfacine monotherapy with extended release guanfacine plus either amphetamine or MPH.^156^ That study is also included in this updated review. Two studies assessed adverse events between ATX and unspecified stimulants,^198^ and between MPH and DEX.^199^ The remaining four studies compared growth in patients receiving MPH versus MAS,^200^ DEX versus MPH,^201^ amphetamine versus MPH,^202^ and MPH versus DEX.^203^

This updated systematic review provides results from a larger number of studies comparing FDA-approved pharmacologic agents, especially comparisons of ATX and MPH; however, the SOE for efficacy or safety remains insufficient for most outcomes. There were no new conclusions regarding the effectiveness of pharmacologic treatments as compared to one another other than slightly higher gastrointestinal side effects for patients taking ATX as compared to MPH (SOE low).

### Strength of Evidence—Pharmacologic Versus Pharmacologic

Table 10 summarizes the SOE for comparisons of pharmacologic therapies based on this report’s included studies. Small numbers of studies with variable quality demonstrating inconsistent and imprecise findings caused insufficient SOE grades for all outcomes other than GI symptoms.

Table 10 Strength of evidence for major outcomes—comparisons of pharmacologic treatments

Outcome SOE Grade | No. Studies/Design (N Patients) Age Category | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Findings
Changes in standardized symptom scores Insufficient | 1 RCT and 1 Obs (379) 7–17 | High | Direct | Inconsistent | Imprecise | Unclear | SOE was insufficient across these 2 studies because of heterogeneity in outcome measures, inconsistency in findings, and high risk of bias. ^118, 156^
Acceptability of treatment-Discontinuation Rate Insufficient | 1 Obs (130) 7–17 | Medium | Direct | NA | Imprecise | None | SOE was insufficient because of the sample size and risk of bias related to the assessment of adherence.^123^
Behavior changes Insufficient | 1 Obs (130) 7–17 | Medium | Direct | NA | Imprecise | None | SOE was insufficient because of the study design and limitations in the pre-post assessment of behavior changes.^123^
Cardiac arrhythmias Insufficient | 1 Obs (750) 7–17 | High | Direct | Consistent | Imprecise | None | SOE was insufficient because of the risk of bias in the one observational study identified.^110^
Changes in appetite Insufficient | 3 Obs (1,966) 7–17 | Medium | Direct | Inconsistent | Imprecise | None | SOE was insufficient because of the risk of bias and lack of consistency in the observational studies.^121, 123, 151^
Conduction abnormalities Insufficient | 1 Obs (1,424) 7–17 | Medium | Direct | NA | Imprecise | None | SOE was insufficient because only one observational study was available and there was a risk that the outcome would not be identified.^151^
Elevated blood pressure Insufficient | 2 Obs and 1 RCT (2,382) 7–17 | High | Direct | Inconsistent | Imprecise | Unclear | SOE was insufficient because of the risk of bias in the 3 studies.^110, 151^ ^157^
Gastrointestinal symptoms Low | 3 Obs (1,966) 7–17 | Medium | Direct | Consistent | Imprecise | None | The proportion of patients reporting gastrointestinal effects or disease was small in all 3 studies and slightly higher for ATX than MPH.^121, 123, 151^
Increased heart rate Insufficient | 3 Obs and 1 RCT (1137) 7–17 | Low | Direct | Consistent | Imprecise | Unclear | SOE was insufficient because of the risk of bias and lack of consistent outcome assessment.^110, 121, 123, 157^
Sleep disturbance Insufficient | 1 Obs (130) 7–17 | Medium | Direct | NA | Imprecise | None | SOE was insufficient because only one small observational study was identified, and because of the risk of bias in the assessment of the outcome measure.^123^
Suicide ideation Insufficient | 1 Obs (1424) 1 Obs (NR) 7–17 | Medium | Direct | Consistent | Imprecise | None | SOE was insufficient because of study heterogeneity and risk that the outcome measure was not detected.^121, 151^
Tics or other movement disorders Insufficient | 2 Obs (1554) 7–17 | Medium | Direct | Consistent | Imprecise | None | SOE was insufficient because of study heterogeneity and risk that the outcome measure was not detected.^123, 151^

Abbreviations: ATX-atomoxetine; ECG=electrocardiogram; MPH=methylphenidate; NA=not applicable; Obs=observational; RCT=randomized controlled trial; SOE=strength of evidence; XR=extended release

### Key Points for Pharmacologic Versus Nonpharmacologic

- MPH decreases appetite and causes more sleep disturbance than supplements including gingko biloba, ningdong granule, or omega-3/6 fatty acids (SOE=low).
- Evidence identified in this systematic review was insufficient for all other outcomes.

### Detailed Synthesis—Pharmacologic Versus Nonpharmacologic

For this KQ 2 comparison, we identified nine articles^114, 124, 131, 141, 146, 147, 155, 189, 192^ representing seven RCT studies published between 2009 and 2016 that met our inclusion criteria. There was a total of 1,072 participants with a mean age ranging from 8.11 to 16.8, and the majority were male (65% to 85.3%). Country sites varied, with the majority conducted in the UK or Europe (n=3). More than half the studies (n=5) were government-sponsored research, most were single site (n=5), and the majority of studies recruited participants from specialty clinics (n=5). Study characteristics are in Table 11.

Table 11 Characteristics of included studies

Characteristic | Value
Study design, number of studies
RCTs | 7
Combined number of patients; range of % males | 1,072; 65.0% to 85.3%
Range of mean ages, years | 8.11 to 16.8
Study years | 2009–2016
Length of intervention/follow-up period | 6 weeks to 8 years
Countries, number of studies
Asia | 1
UK or Europe | 3
Middle East | 1
South America | 1
USA | 1
Funding source, number of studies
Government | 5
Industry | 1
Nongovernment, nonindustry | 1
Study Sites, number of studies
Single site | 5
Multisite | 2
Setting, number of studies
Specialty clinic | 5
Primary clinic | 1
Academic setting | 1
Interventions, number of studies
Supplements | 3
Neurofeedback | 3
Behavioral therapy | 1
Physical exercise, education, behavioral modification | 2
Pharmaceutical intervention and dosage, number of studies
Methylphenidate | 7
0.3–1 mg/kg/day | 6
1.5 mg/kg/day | 1
Timing of last outcome assessment, number of studies
Short-term: ≤3 months | 5
Long-term: 6+ months | 2
Change in standardized scale outcomes, number of studies
ADHD Rating Scale–Parent | 3
ADHD Rating Scale–Teacher | 2
Barkley Rating Scale | 1
Clinician Global Impression–Clinician | 1
Clinician Global Impression–Parent | 1
Visual and Auditory Continuous Performance | 1
Other outcomes, number of studies
Behavior changes (sadness, aggression, irritability, anxiety, depression) | 7
Academic performance | 3
Incarceration | 2
Motor vehicle collision | 1
Sleep | 1
Adverse effects of treatment, number of studies
Height and weight change | 1
Gastrointestinal symptoms (nausea, dyspepsia, stomach pain) | 2
Sleep disturbances (insomnia, hypersomnia, trouble falling asleep) | 4
Changes in appetite (suppression, decreased, increased) | 3

Abbreviations: ADHD=attention deficit hyperactivity disorder; RCT=randomized controlled trial

Of the 7 RCTs, MPH was the primary pharmaceutical intervention. Four trials were 3-arm studies comparing MPH alone or in combination with a nonpharmacologic intervention. The dosage of MPH was clinically adjusted according to tolerability and efficacy, ranging from 0.3 mg/kg per day to 1.5 mg/kg per day. Comparators in the trials included supplements (n=3; gingko biloba, omega-3/6, and ningdong), neurofeedback (n=3), behavioral therapy (n=1), or a combination of behavioral therapy, education, and physical activity (n=2). The duration of studies ranged from 6 weeks to 8 years.

#### Outcome Measures

The selected outcome measures varied considerably across the 7 included studies (Table 11). Change in the ADHD rating scale for parent (n=3) and teacher (n=2) was the most commonly used outcome measure. Behavioral changes and academic performance were also commonly measured outcomes.

We identified three RCTs (2 good quality, 1 poor quality) comparing MPH with a supplement of gingko biloba,^155^ ningdong granule,^141^ or omega-3/6 fatty acid.^114^ The poor-quality study^114^ was unblinded and had high withdrawals (which differed between arms). Sample sizes were small, consisting of 50 to 90 participants, with one 3-arm trial comparing the combination of MPH plus omega-3/6. Changes in the ADHD Rating Scale were the primary outcome for all three trials. Individual study findings suggest that gingko biloba was less effective while ningdong granule and omega-3/6 had effects similar to MPH although the SOE was insufficient given the small overall sample size, short-term outcomes (6–8 weeks for the two good-quality RCTs), and lack of consistency and precision in the outcome measure.

Four RCTs (1 good quality, 2 fair quality, 1 poor quality) compared MPH with neurofeedback or^131, 147^ behavioral therapy,^146, 147, 192^ and a 3-arm trial combined MPH with neurofeedback.^124, 189^ Sample sizes were small in two of the trials (n=57 and 91) and large (n=579) in the 8-year follow-up study.^146, 147, 192^ The primary outcome measures varied among the trials. Study quality was reduced because of lack of blinding and variation in outcome measurement.

Table H-5 in Appendix H summarizes these findings across the 7 studies.

#### Adverse Effects of Supplementation

Adverse effects were identified in four of the included studies.^114, 131, 141, 155^ Changes in gastrointestinal symptoms (nausea, dyspepsia, stomach pain), sleep disturbances (insomnia, hypersomnia, trouble falling asleep), and changes in appetite (suppression, decreased, increased) were measured. A higher proportion of participants experienced adverse effects on sleep (low SOE) or appetite (low SOE) when assigned to the MPH or combined group with MPH as compared to the nonpharmacologic interventions in three studies.^114, 141, 155^ In the fourth study, sleep quality was not affected by any of the received interventions.^131^ Table H-6 in Appendix H summarizes the proportion of participants with adverse effects.

### Findings in Relation to What Is Already Known—Pharmacologic Versus Nonpharmacologic

Previous reviews have examined the relationship between pharmacologic and nonpharmacologic treatments comparing omega-3/6 with placebo.^204, 205^ Previous reviews have not included neurofeedback as an intervention of interest. Our summary findings directly comparing MPH with the supplements of gingko biloba, ningdong granule, or omega-3/6 fatty acids have not been reported in previous reviews. We found insufficient SOE that gingko biloba, ningdong granule, or omega-3/6 supplements produced greater improvements in changes in standardized symptom scores (ADHD Rating Scale) compared to MPH. Several limitations existed among this literature including small sample sizes, and measuring only short-term outcomes in the good-quality studies.

The 2011 report^4^ found that the evidence on long-term outcomes of MPH treatment was sparse and inconclusive. One exception to this was the study by Molina et al.^146, 192^ (also included in this updated review) that showed reduced ADHD symptoms in a mostly male sample with ADHD combined type following 14 to 24 months of MPH treatment.

The 2011 report^4^ also reported on adverse effects of pharmacologic interventions. The findings from that report were determined to be inconclusive due to information from observational studies and uncontrolled extensions to clinical trials. However, that review did not examine adverse effects of pharmacologic treatments when compared with supplements (i.e., gingko biloba, ningdong granule, and omega-3/6). Generally, a higher proportion of adverse effects was reported with MPH or combination of supplements and MPH compared with supplement (low SOE for both sleep disturbances and decreased appetite). Our SOE comparing MPH with these supplements are limited due to small sample sizes, overall quality of the studies, and assessment of short-term outcomes.

### Strength of Evidence—Pharmacologic Versus Nonpharmacologic

Table 12 summarizes the SOE for pharmacologic versus nonpharmacologic treatments based on this report’s included studies. Small numbers of studies with potential limitations and inconsistent and imprecise findings caused insufficient SOE grades for all outcomes other than sleep disturbance and changes in appetite.

Table 12 Strength of evidence for major outcomes—comparisons between pharmacologic and nonpharmacologic treatments

Outcome SOE Grade | No. Studies/Design (N Patients) Age Category | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Findings
Changes in standardized symptom scores Insufficient | 5 RCTs (356) 7–17 | Medium | Direct | Inconsistent | Imprecise | Unclear | SOE was insufficient because of the small overall sample size and lack of consistency and precision in the outcome measure.^114, 124, 141, 147, 155, 189^
Behavior changes Insufficient | 3 RCTs (274) 7–17 | Medium | Direct | Inconsistent | Imprecise | None | SOE was insufficient because of the small overall sample size and lack of consistency and precision in the outcome measure.^114, 131, 141^
Aggression Insufficient | 1 RCT (436) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was insufficient because of the risk of bias in the single RCT identified.^146, 192^
Depression or anxiety Insufficient | 2 RCTs (486) 7–17 | Medium | Direct | Consistent | Imprecise | Unclear | SOE was insufficient because of the small overall sample size and lack of consistency and precision in the outcome measure.^146, 155, 192^
Academic performance Insufficient | 1 RCT (436) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was insufficient because of the risk of bias in the single RCT identified.^146, 192^
Incarceration Insufficient | 1 RCT (436) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was insufficient because of the small overall sample size and lack of consistency and precision in the outcome measure.^146, 192^
Motor vehicle collisions Insufficient | 1 RCT (436) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was rated insufficient because of the small overall sample size and lack of consistency and precision in the outcome measure.^146, 192^
Changes in appetite Low | 3 RCT (212) 7–17 | Medium | Direct | Consistent | Imprecise | None | All three studies found the MPH medication group to have a significantly greater number of participants with decreased appetite when compared to supplementation by ningdong, omega-3/6 or gingko biloba.^114, 141, 155^
Elevated blood pressure Insufficient | 1 RCT (493) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was insufficient because of the small overall sample size and lack of consistency and precision in the outcome measure.^146, 192^
Gastrointestinal symptoms Insufficient | 2 RCTs (162) 7–17 | Medium | Direct | Inconsistent | Imprecise | None | SOE was insufficient because of the small overall sample size and lack of consistency and precision in the outcome measure.^114, 141^
Increased heart rate Insufficient | 1 RCT (507) 7–17 | Medium | Direct | NA | Imprecise | Unclear | SOE was rated insufficient because of the small overall sample size and lack of consistency and precision in the outcome measure.^146, 192^
Sleep disturbance Low | 4 RCTs (324) 7–17 | Medium | Direct | Inconsistent | Imprecise | None | There was a greater proportion of sleep disturbance outcomes in the MPH medication group compared to supplementation by ningdong granule, gingko biloba, or neurofeedback.^114, 141, 155^ A fourth study found no significant difference in sleep scores between interventions^131^
Weight decrease Insufficient | 1 RCT (50) 7–17 | Medium | Direct | NA | Imprecise | None | SOE was insufficient because of the sample size in the single study and risk of bias measuring the outcome.^155^

Abbreviations: MPH=methylphenidate NA=not applicable; Obs=observational; RCT=randomized controlled trial; SOE=strength of evidence

### Key Points for Nonpharmacologic Versus Nonpharmacologic/Placebo

- There is insufficient evidence based on the studies identified in this systematic evidence review to evaluate the effectiveness of neurofeedback in reducing ADHD symptoms.
- There is some evidence that cognitive training strategies such as the computer-based Cogmed cognitive training program may reduce ADHD symptoms in the short term but not the long term (SOE=low).
- Cognitive behavioral therapy resulted in improvement in ADHD symptoms (SOE=low).
- Child or parent training did not demonstrate differences in academic performance (SOE=low).
- Child or parent training improves ADHD symptoms (SOE=moderate).
- Omega-3 fatty acid supplementation was no different than placebo on ADHD symptoms (SOE=moderate).

#### Categories of Interventions for This Comparison

We organized the comparison of nonpharmacologic versus nonpharmacologic/placebo treatments into the following seven intervention categories:

1. Neurofeedback
2. Cognitive training
3. Cognitive behavioral therapy (CBT), focusing on the development of specific skills for patients to be aware of their symptoms of ADHD and developing strategies to minimize the effects of these symptoms
4. Child or parent training or behavioral intervention
5. Dietary supplementation with omega-3/6 fatty acids
6. Herbal or dietary approaches
7. Other approaches

Other approaches included community programs and programs that addressed mentoring and parent support, multisystemic intervention at school and with parents, in-home family training intervention, a general parenting program, using melatonin as an adjunct treatment, acupuncture, and a homeopathic intervention). Studies were included in these comparisons that had subjects in all study arms that received other ADHD treatment, including psychostimulants.

As previously described, there is insufficient evidence to directly compare omega-3/6 fatty acid supplementation to MPH or other psychostimulants. The effectiveness of omega-3/6 for the treatment of ADHD symptoms was not included in the 2011 report. This current review identified a single previous systematic review and meta-analysis (Bloch and Qawasmi^204^) comparing omega-3 fatty acid supplementation with placebo and found a small but statistically significant benefit on ADHD symptoms. The Bloch and Qawasmi systematic review included ten trials of 699 children. Only two trials found a benefit and the overall effect size from the meta-analysis was small (0.31). The meta-analysis conducted within this report found no benefit for omega-3 fatty acid supplementation. In summary, omega-3/6 supplementation is unlikely to have benefit.

Of the 7 intervention categories, only 2 had data from the previous systematic review thereby allowing us to discuss our new findings in relation to what is already known: (1) child or parent training or behavioral interventions and (2) other approaches. These findings are described in their corresponding sections below.

### Detailed Synthesis—Overview

For this KQ 2 comparison, we identified 61 articles^107–109, 111, 112, 115–117, 119, 122, 125–129, 131–134, 136–140, 142–147, 149, 150, 152–154, 158–161, 163–165, 167–172, 174, 175, 184–188, 190–195^ representing 50 studies that met our inclusion criteria. All but two studies were RCTs.^115, 127^ Of the 47 RCTs, 28 were rated as good quality,^107–109, 112, 116, 119, 122, 125, 126, 129, 131–134, 139, 142, 143, 150, 152, 158, 160, 161, 164, 167–169, 172, 174^ 19 as fair quality,^111, 117, 128, 137, 138, 140, 144–147, 149, 153, 154, 159, 163, 165, 170, 171, 175^ and 1 as poor quality.^136^ The two observational studies were was rated as fair quality.^115, 127^ Of these, 20 were multisite studies, 29 were single-site studies, and one did not report the number of sites. Fifteen studies included patients in the United States, 19 were conducted in Europe, and 16 included patients from the Middle East, Asia, Australia, or New Zealand. Government funding supported 26 studies, industry supported 3 studies, nongovernment and nonindustry funding supported 11 studies. External funding was either not provided or not reported for 15 studies.

The 50 studies reported 54 comparisons of a nonpharmacologic therapy with either another nonpharmacologic therapy or no therapy (e.g., a placebo intervention, usual care, or a waitlist control). Of the 7 intervention categories, 5 evaluated neurofeedback; 10, cognitive training; 2, CBT; 13, child or parent training or behavioral intervention; 8, dietary supplementation with omega-3/6 fatty acids; 6, herbal or dietary approaches; and 9, other approaches. Details of these comparisons are reported below, organized by intervention category.

### Detailed Synthesis—Neurofeedback

Neurofeedback is a computer-aided type of nonpharmacologic treatment for ADHD that is based on biofeedback principles. Treatment typically involves patients using a computer monitor that shows brainwave activity through EEG. In the neurofeedback process, patients are trained to adjust their attention and thereby their brainwave activity. Four good-quality^116, 131, 132, 160, 186, 193, 194^ and 1 fair-quality^147^ studies representing 353 patients evaluated neurofeedback. Findings are summarized by outcome and described in Table H-7 in Appendix H. These studies had short periods of intervention, with only one study^116^ describing findings to 6 months. Therefore, the overall SOE was insufficient.

#### Acceptability of Treatment

Only one study examined parent-rated motivation of children to participate in treatment and the effectiveness of treatment, finding no difference between neurofeedback and the attention skills control condition.^132, 193, 194^ The SOE was insufficient given that the evidence was from only one study which might have been underpowered.

#### Behavior Changes

Only one small but good-quality study assessed behavior changes associated with a 12-week course of neurofeedback sessions. This study found no statistically significant differences in postintervention mean scores for the Inattention and Hyperactivity/Impulsiveness subscales of the Strengths and Weaknesses of ADHD and Normal Behavior (SWAN) questionnaire. The single small study resulted in an insufficient SOE.^131^

#### Changes in Standardized Symptom Scores

One study found a statistically significant decrease in ADHD symptoms using a standard scale comparing neurofeedback with an attention skills control condition.^132, 193, 194^ A second study found no difference between neurofeedback and cognitive training, but did find significant improvements in ADHD symptoms according to parent and teacher reporting for neurofeedback compared with control.^160, 186^ A third study compared neurofeedback with standard pharmacologic treatment and a behavioral treatment and found that the group treated with neurofeedback showed greater improvement in a continuous performance test score when compared with each of the other groups.^147^ Finally, a fourth study did not find any significant changes between children receiving neurofeedback versus those receiving treatment as usual.^116^ The SOE was insufficient given the small sample sizes of all studies and the variation in outcomes reported.

#### Sleep Disturbance

Only one study assessed sleep disturbance associated with a 12-week course of neurofeedback sessions. This study found no significant difference in postintervention mean scores in the Sleep Disturbance Scale for Children (SDSC) between neurofeedback and physical activity. The single small study resulted in an insufficient SOE.^131^

#### Adverse Effects of Neurofeedback

No adverse effects from neurofeedback were reported.

### Strength of Evidence—Neurofeedback

Table 13 summarizes the SOE for neurofeedback based on this report’s included studies. Inconsistent findings and heterogeneous interventions caused the insufficient SOE grades.

Table 13 Strength of evidence for major outcomes—neurofeedback

Outcome SOE Grade | No. Studies/Design (N Patients) Age Category | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Findings
Acceptability of treatment Insufficient | 1 RCT (102) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient because only one trial that might have been underpowered was identified.^132, 193, 194^
Behavior change Insufficient | 1 RCT (103) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient given findings from only one small study.^131^
Changes in standardized symptom scores Insufficient | 4 RCTs (353) 7–17 | Low | Direct | Inconsistent | Imprecise | Unclear | SOE was insufficient because of the small sample size in the 4 trials and the variation in outcomes reported.^116, 132, 147, 160, 186^
Sleep disturbance Insufficient | 1 RCT (103) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient given findings from only one small study.^131^

Abbreviations: NA=not applicable; Obs=observational; RCT=randomized controlled trial; SOE=strength of evidence

### Detailed Synthesis—Cognitive Training

Six good-quality^119, 122, 126, 132, 160, 174, 186, 187^ and 2 fair-quality^115, 163^ studies representing 768 patients evaluated cognitive training interventions. All but one study involved computer-based cognitive training programs, and of those five used a specific brand of intervention (Cogmed). Findings are summarized by outcome and described in Table H-8 in Appendix H. Meta-analysis was not possible given heterogeneity in outcomes and time frame. The specific findings detailed in the table are described below.

#### Academic Performance

A single, good-quality RCT found no significant treatment effects in improvement in Wide Range Achievement Test 4 Progress Monitoring Version (WRAT) scores compared with a low-level (placebo) working memory training program that was identical to active intervention with respect to the types of training games utilized and the number of training trials per session, but for which difficulty level was not adjusted according to each user’s performance parameters. ^119^ The SOE was insufficient given the small size of the single included study.

#### Acceptability of Treatment

A single study examined parent-rated motivation of children to participate in treatment and the effectiveness of treatment, finding no difference between cognitive training and neurofeedback.^132, 193, 194^ The SOE was insufficient given the small size of the single included study.

#### Behavior Changes

A good-quality RCT found no significant between-group differences in scores on the Disruptive Behavior Disorder Rating Scale (DBDRS) compared with a partially-active-condition where inhibition and cognitive-flexibility were trained and the working memory-training task was presented in placebo-mode, or to a full placebo-condition.^122^ The SOE was insufficient given the small size of the single included study.

#### Changes in Standardized Symptom Scores

Of studies examining the Cogmed cognitive training programs,^115, 119, 126, 163, 174, 187^ three of these studies^119, 126, 174, 187^ found no significant changes on standard ADHD scales compared with low-level working memory games or a waitlist control. Two studies found a significant improvement on standardized scales.^115, 163^ Of those, one compared the Cogmed intervention with a waitlist control, and at 4 months the treatment group had significantly better scores on parent report on the ADHD Index, Conners Cognitive Problems/Inattention, Conners Hyperactivity Parent, and BRIEF Metacognition Index.^115^ No teacher measures showed any significant changes. In the other study, there was improvement at 2 and 6 months on the parent rated BRIEF Metacognition Index, and at 2 months (but not 6 months) on the BRIEF parent-rated behavioral index.^163^

Three other studies examined computer-based cognitive training programs.^122, 132, 160, 186, 193, 194^ One compared the Braingame program to a computer game that did not have any cognitive training characteristics, finding no significant effect of this type of training.^122^ The other two were studies comparing neurofeedback with computer-based cognitive training.^132, 160, 186, 193, 194^ There was no difference between cognitive training and control in one,^160, 186^ but neurofeedback was found to be superior to both. The other directly compared the two interventions and found neurofeedback superior to cognitive attention skills training on a standardized ADHD scale.^132, 193, 194^

Overall the evidence from these studies provided low SOE that cognitive training improved standardized symptoms scores.

#### Adverse Effects of Cognitive Training

No adverse effects from cognitive training were reported in any of the included studies.

### Findings in Relation to What Is Already Known—Cognitive Training

The 2011 review did not evaluate cognitive training. Our current systematic review demonstrates that cognitive training may improve symptoms scores (SOE=low).

### Strength of Evidence—Cognitive Training

Table 14 summarizes the SOE for cognitive training based on this report’s included studies. Small numbers of studies with imprecise findings caused insufficient SOE grades for all outcomes other than changes in standardized symptom scores which had low SOE for a benefit with cognitive training.

Table 14 Strength of evidence for major outcomes—cognitive training

Outcome SOE Grade | No. Studies/Design (N Patients) Age Category | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Findings
Academic performance Insufficient | 1 RCT (85) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient because only one small trial was identified.^119^
Acceptability of treatment Insufficient | 1 RCT (102) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient because only one small trial was identified.^132, 193, 194^
Behavior changes Insufficient | 1 RCT (89) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient because only one small trial was identified.^122^
Changes in standardized symptom scores Low | 9 RCTs (768) 7–17, all through 17 | Medium | Direct | Inconsistent | Imprecise | None | Cognitive training may improve symptom scores.^115, 119, 122, 126, 132, 160, 163, 174, 186, 187, 193, 194^

Abbreviations: NA=not applicable; Obs=observational; RCT=randomized controlled trial; SOE=strength of evidence

### Detailed Synthesis—Cognitive Behavioral Therapy

One good-quality^164^ and 1 fair-quality^117, 185^ study representing 278 patients evaluated CBT. Findings are summarized by outcome and described below and in Table H-9 in Appendix H.

#### Changes in Standardized Symptom Scores

Both studies found a statistically significant improvement in ADHD symptom scores for the CBT program as opposed to the control condition after the initial treatment (low SOE). One fair-quality study^117, 185^ followed patients through 12 months and found the CBT condition maintained superiority in terms of ADHD scale scores. In addition, this study found that there was a greater improvement in the CBCL conduct disorder/oppositional defiant disorder subscale both immediately after treatment and at 12 months.

#### Depression or Anxiety

The fair-quality study^117, 185^ examined changes in the depression anxiety scale scores and found that the CBT group had greater improvement in depression and anxiety scores as opposed to the control group at 3 months and that the depression score improvements were maintained at 12 months. The SOE was insufficient given the evidence coming from only a single included study with medium risk of bias.

#### Adverse Effects of CBT

No adverse effects from CBT were reported.

### Strength of Evidence—Cognitive Behavioral Therapy

Table 15 summarizes the SOE for CBT based on this report’s included studies. Small numbers of studies with imprecise findings caused insufficient SOE grades for all outcomes other than changes in standardized symptom scores which had low SOE for a benefit from cognitive behavioral therapy.

Table 15 Strength of evidence for major outcomes—cognitive behavioral therapy

Outcome SOE Grade | No. Studies/Design (N Patients) Age Category | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Findings
Changes in standardized symptom scores Low | 2 RCTs (278) 7–17 | Low | Direct | Consistent | Imprecise | Suspect (reasons for drop out not adequately described) | There was statistically significant improvement in ADHD symptoms associated with CBT relative to usual care or a limited CBT intervention.^117, 164, 185^
Depression or anxiety Insufficient | 1 RCT (159) 7–17 | Medium | Direct | NA | Imprecise | Suspect (reasons for drop out not adequately described) | SOE was insufficient because only one small trial was identified.^117, 185^

Abbreviations: ADHD=attention deficit hyperactivity disorder; CBT=cognitive behavioral therapy; NA=not applicable; RCT=randomized controlled trial; SOE=strength of evidence

### Detailed Synthesis—Child or Parent Training or Behavioral Interventions

Ten good-quality RCTs,^108, 112, 129, 134, 150, 152, 161, 167–169^ 2 fair-quality RCTs,^138, 159^ and 1 fair-quality observational study^127^ representing 1,583 patients evaluated child or parent training or behavioral interventions. These included a range of different types of non-CBT behavioral interventions including organizational skills, social skills, attention skills, positive parenting, psychoeducational, sleep hygiene/behavioral, or parent or teacher behavioral training interventions. Findings are summarized by outcome and described below and in Table H-10 in Appendix H Note that the interventions were mixed in terms of their strategies: some were interventions which helped parents learn how to cope with their own emotions, most strategies focused on how parents could manage specific behaviors from their children with ADHD.

#### Academic Performance

Three RCTs of child-focused interventions evaluated academic performance outcomes. These trials found no change compared with the control condition (low SOE). One of these trials evaluated organizational skills training,^108^ one evaluated social skills training,^161^ and one evaluated an adolescent-specific, skills-based therapy called Supporting Teens’ Autonomy Daily (STAND).^159^

#### Acceptability of Treatment

The single RCT that assessed the outcome of acceptability of treatment found that parent satisfaction with process was superior with the behavioral intervention compared to the control group.^167^ The SOE was insufficient given the small size of the single included study.

#### Changes in Standardized Symptom Scores

Three RCTs examined psychoeducational programs for parents or families of children with ADHD.^112, 129, 168^ All three found significant improvement on some standard measures of ADHD symptoms with child or parent training (moderate SOE). One study that examined children 6 to 16 years of age compared psychoeducation with a general counseling control and found significant improvement in overall ADHD scores for the intervention group compared with control.^112^ Another study comparing psychoeducation with a control in children 5–18 years of age found significantly better ADHD scores on a standard scale at 12 weeks for overall symptoms and attention, and at 12 months there was significant difference only on inattention/cognition standard scores.^168^ Another study compared a structured psychoeducation program for family members of children with ADHD to usual care, with outcomes assessed at 6 weeks and 6 months.^129^ This study demonstrated significant improvements over time associated with psychoeducation in the CPRS index, CPRS inattention and cognition, and CPRS hyperactivity and impulsivity.

Other parenting interventions included a positive parenting program that did not find a strong effect on ADHD symptoms, but did find a significant effect on overall impairment rating compared to a behavioral parenting program and an even greater effect compared to a waitlist control.^167^ There was a significant improvement in ADHD symptoms when comparing the positive parenting program to the waitlist control. Another parenting intervention that evaluated sleep hygiene and behavioral training for parents found improvements at 6 months in all parent-reported ADHD scores, but no difference between controls on teacher reported scores.^169, 184^ Another parent study compared children on MPH who received MPH alone or medication plus parent training; this study found no significant difference between groups.^127^

A combined behavioral training intervention for parents and teachers found no changes in ADHD scores at 10 weeks as reported by parents or teachers, but at 3 months postintervention did find improvement in parent reported ADHD scale scores, but not on teacher report.^150^ Another combined intervention study compared a combination of parent group and child group interventions with parent intervention alone or community care in general.^152^ This study found improvement on symptoms of the combined groups, compared to both comparison conditions at 3 months. At approximately 6 months the improvements in parent reported ADHD symptoms were maintained. In terms of functional impairment there was no difference at 3 months between groups, while at 6 months the parent-reported, but not teacher-rated, functional impairment was improved in the intervention as compared to the parent group alone or the community control. One study examined social skills for children with a parallel parent group and found significant changes on the CBCL attention problem subscale as compared to a control condition including treatment as usual.^138^ Another study evaluated an adolescent-specific, skills-based therapy called STAND over the course of 6 months.^159^ This study found that the STAND intervention was associated with statistically significant improvements in standardized scores that assessed the severity of ADHD symptoms. Another study that evaluated the impact of 10 parent-child weekly cognitive-functional (Cog-Fun) intervention sessions found that the Cog-Fun intervention was associated with significant improvements in the CPRS-R global index total score when rated by parents but not when rated by teachers.^134^

In summary, of the 11 studies that included a parent intervention component, 9 showed improvement in some standard measure of ADHD symptoms, often on parent report (Moderate SOE). One of the two studies that did not show improvement on ADHD symptoms did show improvement on functional impairment.

#### Depression or Anxiety

No differences in depression and anxiety were found in an RCT that evaluated sleep hygiene counseling for parents combined with behavior therapy.^169, 184^ The SOE was insufficient given the evidence of a single included study.

#### Functional Impairment

A good-quality RCT found that Child Life and Attention Skills Treatment was associated with improved parent and teacher CGI scores relative to parent training alone or no intervention.^152^ Another good-quality RCT^167^ found that the Strategies to Enhance Positive Parenting (STEPP) program was more effective at reducing functional impairment than a waitlist control, but not more effective than traditional behavioral parent training. Another study compared a structured psychoeducation program for family members of children with ADHD to usual care, with outcomes assessed at 6 weeks and 6 months.^129^ This study demonstrated significant improvements over time associated with CGI global improvement, but not in the CTRS index of CGI severity of illness. The SOE was insufficient given the evidence of a single included study.

#### Sleep Disturbance

Sleep habits at 6 months were improved in a good-quality study which randomized patients to an intervention that combined sleep hygiene counseling for parents and behavior therapy. SOE was insufficient given imprecision of the findings and that there was only one study^169, 184^

#### Workforce Participation

A single RCT found that an intervention that combined sleep hygiene counseling for parents and behavior therapy found that the intervention was associated with fewer days late for work and fewer missed days of work for the parents (insufficient SOE)^169, 184^

#### Adverse Effects of Child or Parent Training or Behavioral Interventions

No adverse effects of these behavioral treatments were examined.

### Findings in Relation to What Is Already Known—Child or Parent Training or Behavioral Interventions

The 2011 report^4^ identified 31 studies that evaluated parent behavior training for preschoolers with disruptive behavior disorders. Of these, three RCTs included only preschoolers who exhibited ADHD symptoms but who were not necessarily formally diagnosed with ADHD.^206–208^ All three RCTs demonstrated significant improvement in the preschoolers’ behavior or symptoms relative to usual care only. In contrast, this updated review provides results from 12 RCTs and 1 observational study that evaluated the effectiveness of either parent or child behavior training on outcomes among children with a wider age range who had been formally diagnosed with ADHD. Behavioral therapy appears effective for certain children with ADHD, however there are still questions related to the comparative effectiveness with pharmacotherapy alone or in combination with behavioral therapy. This reflects the complex nature of ADHD and the specific factors related to the child including age.

### Strength of Evidence—Child or Parent Training or Behavioral Interventions

Table 16 summarizes the SOE for child or parent training or behavioral interventions based on this report’s included studies. Small numbers of studies with imprecise findings caused insufficient SOE grades for all outcomes other than academic performance (SOE=low) and changes in standardized symptom scores (SOE=moderate) which did not demonstrate an effect of child or parent training/behavioral interventions.

Table 16 Strength of evidence for major outcomes—child or parent training or behavioral interventions

Outcome SOE Grade | No. Studies/Design (N Patients) Age Category | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Findings
Academic performance Low | 2 RCTs (356) 6 and under, 7–17 | Low | Direct | Consistent | Imprecise | None | There were no differences in academic performance associated with organizational skills or social skills training relative to no intervention.^108, 161^
Acceptability of treatment Insufficient | 1 RCT (120) All through 17 | Low | Direct | NA | Imprecise | None | SOE was insufficient because only one small trial was identified.^167^
Changes in standardized symptom scores Moderate | 8 RCTs, 1 Obs (966) 7–17, all through 17 | Low | Direct | Consistent | Imprecise | None | There was a significant improvement in ADHD symptoms associated with child or parent training or sleep hygiene.^112, 127, 129, 138, 150, 152, 167–169, 184^
Depression or anxiety Insufficient | 1 RCT (244) All through 17 | Low | Direct | NA | Imprecise | None | SOE was insufficient because only one small trial was identified.^169, 184^
Functional impairment Insufficient | 1.RCT (199) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient because only one small trial was identified.^152^
Sleep disturbance Insufficient | 1 RCT (244) All through 17 | Low | Direct | NA | Imprecise | None | SOE was insufficient because of findings from only one study which was imprecise^169, 184^
Workforce participation Insufficient | 1 RCT (244) All through 17 | Low | Direct | NA | Imprecise | None | SOE was insufficient because of findings from only one study which was imprecise.^169, 184^

Abbreviations: NA=not applicable; Obs=observational; RCT=randomized controlled trial; SOE=strength of evidence

### Detailed Synthesis—Omega-3/6 Fatty Acid Supplementation

We identified five good-quality,^109, 133, 139, 142, 143^ two fair-quality,^154, 165^ and one poor-quality studies^136^ representing 1,130 patients evaluated essential fatty acid supplementation. Seven of these trials compared essential fatty acid supplementation with placebo. Of these, the active intervention was omega-3 alone in four trials,^133, 136, 142, 165, 191^ omega-6 alone in 1 trial,^154^ and a combination of omega-3 and omega-6 in 2 trials.^139, 195^ Treatment duration ranged between 7-weeks and 6-months. The enrolled children ranged 6–18 years of age and the range of included male children was 59.4 percent to 77.3 percent across the trials. Inclusion of ADHD subtypes varied with a mixed grouping of ADHD subtypes included in 3 of the trials, a specific oppositional sub-type in one trial and three trials did not specify an ADHD sub-type of included children. One of the 8 trials^165^ measured outcomes of ADHD symptoms with scales that were not part of our inclusion criteria and were excluded from the meta-analysis. The remaining 7 trials measured ADHD symptoms with the Conners Scale (full or abbreviated version) or the ADHD Rating Scale. Findings are summarized below by outcome below and described in Table H-11 in Appendix H. Overall, supplementation was not observed to be effective.

#### Behavior Changes

A good-quality RCT did not find a difference in the proportion of patients who were prone to crying or who talked less after supplementation with omega-3 fatty acids, relative to placebo.^191^ The SOE was insufficient given that the imprecision in the findings and the small number of participants who experienced the outcomes of interest.

#### Changes in Standardized Symptom Scores

We conducted meta-analyses of 4 eligible RCTs that reported parent ratings of ADHD total symptoms and 3 eligible RCTs that reported teacher ratings of ADHD total symptoms. These analyses demonstrated no significant differences between omega 3/6 and placebo for either parent or teacher ratings (moderate SOE).

##### Parent Ratings of ADHD Total Symptoms

We summarized four RCTs, with random-effects meta-analysis, examining omega-3/6 supplementation versus placebo only with the outcome of parent-rated total ADHD symptoms.^133, 136, 139, 142, 191, 195^ Effects were consistent and studies demonstrated moderate heterogeneity; however, no statistical evidence was found that omega-3/6 was superior to placebo with the outcome of parent rating of ADHD total symptoms (n=411, SMD -0.32, 95% CI −0.80 to 0.15, I^2^=52.4%, Q=6.3, p=0.098) (Figure 3). The three trials that we excluded from the meta-analysis found no significant differences between omega-3/6 versus placebo, versus usual care, or between eicosapentaenoic acid and versus docosahexaenoiac acid for parent ratings of ADHD total symptoms.

Figure 3 Meta-analysis for effects of omega-3/6 supplementation compared with placebo—parent ratings

CI=confidence interval; SD=standard deviation; SMD=standardized mean difference

Figure 3. Meta-analysis for Effects of Omega-3/6 Supplementation Compared With Placebo–Parent Ratings. This figure displays a forest plot of four studies that compared omega-3/6 supplementation versus placebo with the outcome of parent-rated total ADHD symptoms. The summary odds ratio was SMD -0.32 (95% CI -0.80 to 0.15, I2=52.4%, Q=6.3, p-value=0.098). Effects were consistent and studies demonstrated moderate heterogeneity; however, no statistical evidence was found that omega-3/6 was superior to placebo with the outcome of parent rating of ADHD total symptoms.

##### Teacher Ratings of ADHD Total Symptoms

We summarized three RCTs, with random effects meta-analysis, examining omega-3/6 versus placebo with the outcome of teacher rated total ADHD symptoms.^133, 142, 154, 191^ Effects were fairly consistent and studies were homogeneous; however, we found no statistical evidence that omega-3/6 was superior to placebo with the outcome of teacher rated total ADHD symptoms (n=287, SMD −0.08, 95% CI −0.47 to 0.32, I^2^=0.0%; Q=1.2, p=0.56) (Figure 4). The two RCTs excluded in this meta-analysis^109, 165^ also found no significant difference between omega-3 and placebo or usual care for teacher ratings of ADHD total symptoms.

Figure 4 Meta-analysis for effects of omega-3/6 supplementation compared with placebo—teacher ratings

CI=confidence interval; SD=standard deviation; SMD=standardized mean difference

Figure 4. Meta-analysis for Effects of Omega-3/6 Supplementation Compared With Placebo–Teacher Ratings. This figure displays a forest plot of four studies that compared omega-3/6 supplementation versus placebo with the outcome of teacher-rated total ADHD symptoms. The summary odds ratio was SMD -0.08 (95% CI -0.47 to 0.32, I2=0.0%; Q=1.2, p=0.56). Effects were fairly consistent and studies were homogeneous; however, we found no statistical evidence that Omega 3/6 was superior to placebo with the outcome of teacher rated total ADHD symptoms.

#### Functional Impairment

A good-quality RCT found no difference in Clinical Global Impression scores associated with omega-3 fatty acid supplementation compared with placebo.^139, 195^ The SOE was insufficient given evidence from one small included study.

#### Adverse Effects of Omega-3 Fatty Acid Supplementation

A single good-quality RCT reported the incidence of adverse effects associated with omega-3 fatty acid supplementation compared with placebo.^142, 191^ This trial did not report statistically significant between-group differences for any of the following adverse effects: chemical leukoderma; elevated blood pressure; sleep disturbance; tics or other movement disorders; gastrointestinal symptoms; growth suppression; increased heart rate; personality change; or weight decrease. The SOE was insufficient however given the small number of patients in either arm that experienced any of the outcomes of interest and the inconsistency between positive, negative, and no effects that were observed for individual outcomes at varying time points.

### Findings in Relation to What Is Already Known—Omega-3 Fatty Acid Supplementation

The effectiveness of omega-3/6 for the treatment of ADHD symptoms was not included in the 2011 report.^4^ However, a systematic review and meta-analysis comparing omega-3 fatty acid supplementation with placebo was conducted in 2011 by Bloch and Qawasmi.^204^ Using only PubMed, they searched from database inception to December 2010. Their findings, using fixed-effects meta-analysis, indicated a small significant effect (SMD 0.31, 95% CI 0.16 to 0.47) on ADHD symptoms with omega-3 use associated with improved symptoms. Due to an overlap in search dates, our review includes 3 of the 10 studies that were also included in the Bloch and Qawasmi review. Our inclusion and exclusion criteria differed from that review as we excluded studies where the sample size was less than 50 participants.^209^ Given the differences in measurement and perspective, our review also conducted a separate meta-analysis for teacher- and parent-reported ADHD symptoms whereas the Bloch and Qawasmi review included only the parent- or teacher-reported ADHD symptoms depending on the number of completed ADHD subscales. Our meta-analysis (Figure 3) used random-effects models and corrected the standard errors for a small sample meta-analysis using the Knapp-Hartung method, both techniques that create a more conservative confidence interval.^210^ As such, due to differences in search dates, inclusion/exclusion criteria and analytical approaches, differences in pooled estimates between the two reviews would be expected. Note that given the wider confidence interval within our analysis compared to the Bloch and Qawasmi meta-analysis, we did not find evidence of a benefit.

### Strength of Evidence—Omega-3 Supplementation

Table 17 summarizes the SOE for omega-3 supplementation based on this report’s included studies. Small numbers of studies with imprecise findings caused insufficient SOE for all outcomes other than changes in standardized symptom scores, for which we found moderate SOE for no difference.

Table 17 Strength of evidence for major outcomes—omega-3 fatty acid supplementation

Outcome SOE Grade | No. Studies/Design (N Patients) Age Category | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Findings
Behavior changes Insufficient | 1 RCTs (200) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient because only one trial was identified with imprecise findings and a small number of events of the outcomes of interest.^142, 191^
Changes in standardized symptom scores Moderate | 7 RCTs (795) 7–17 | Low | Direct | Consistent | Precise | None | Two meta-analyses of 4 and 3 good-quality studies respectively found no significant differences between Omega-3/6 and placebo for parent ratings (n=411, SMD −0.32, 95% CI −0.80 to 0.15, I^2^=52.4%, Q=6.3, p=0.098) or teacher ratings of total ADHD symptoms (n=287, SMD −0.08, 95% CI −0.47 to 0.32, I^2^=0.0%; Q=1.2, p=0.56).^133, 136, 139, 142, 143, 154, 190, 191, 195^
Functional impairment Insufficient | 1 RCT (75) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient because only one small trial was identified.^139, 195^
Chemical Leukoderma Insufficient | 1 RCT (200) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient given the small number of patients in either arm that experienced any of the outcomes of interest and the inconsistency between positive, negative, and no effects that were observed for individual adverse effects at varying timepoints.^142, 191^
Elevated blood pressure Insufficient | 1 RCT (200) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient given the small number of patients in either arm that experienced any of the outcomes of interest and the inconsistency between positive, negative, and no effects that were observed for individual adverse effects at varying timepoints.^142, 191^
Sleep disturbance Insufficient | 1 RCT (200) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient given the small number of patients in either arm that experienced any of the outcomes of interest and the inconsistency between positive, negative, and no effects that were observed for individual adverse effects at varying timepoints.^142, 191^
Tics or other movement disorders Insufficient | 1 RCT (200) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient given the small number of patients in either arm that experienced any of the outcomes of interest and the inconsistency between positive, negative, and no effects that were observed for individual adverse effects at varying timepoints.^142, 191^
Gastrointestinal symptoms Insufficient | 1 RCT (200) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient given the small number of patients in either arm that experienced any of the outcomes of interest and the inconsistency between positive, negative, and no effects that were observed for individual adverse effects at varying timepoints.^142, 191^
Growth suppression Insufficient | 1 RCT (200) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient given the small number of patients in either arm that experienced any of the outcomes of interest and the inconsistency between positive, negative, and no effects that were observed for individual adverse effects at varying timepoints.^142, 191^
Increased heart rate Insufficient | 1 RCT (200) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient given the small number of patients in either arm that experienced any of the outcomes of interest and the inconsistency between positive, negative, and no effects that were observed for individual adverse effects at varying timepoints.^142, 191^
Personality change Insufficient | 1 RCT (200) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient given the small number of patients in either arm that experienced any of the outcomes of interest and the inconsistency between positive, negative, and no effects that were observed for individual adverse effects at varying timepoints.^142, 191^
Weight decrease Insufficient | 1 RCT (200) 7–17 | Low | Direct | NA | Imprecise | None | SOE was insufficient given the small number of patients in either arm that experienced any of the outcomes of interest and the inconsistency between positive, negative, and no effects that were observed for individual adverse effects at varying timepoints.^142, 191^

Abbreviations: NA=not applicable; Obs=observational; RCT=randomized controlled trial; SOE=strength of evidence

### Detailed Synthesis—Herbal Interventions or Dietary Approaches

Three good-quality^125, 158, 172^ and 3 fair-quality^111, 140, 144^ studies representing 486 patients evaluated herbal interventions or dietary approaches. Findings are summarized by outcome and described in Table H-12 in Appendix H. A wide range of interventions were evaluated in these studies, including an elimination diet, gingko biloba, Memomet syrup, zinc, and other patented herbal preparations. Although some interventions appeared effective, findings are difficult to interpret in studies that also allowed use of pharmacotherapy.

#### Behavior Changes

One good-quality RCT found that gingko biloba was associated with improved parent and teacher ADHD-RS-Inattention scores but not ADHD-RS-Hyperactivity scores relative to placebo.^158^ One fair-quality RCT found that an 8-week course of vitamin D supplementation given with MPH was associated with improvement in Weekly Parent Ratings of Evening and Morning Behavior (WPREMB) evening symptom scores and total score, but not WPREMB morning scores compared to MPH and placebo.^144^ A third RCT (fair-quality) did not find statistically significant differences between patients on placebo and those taking zinc supplementation.^111^ The variability in interventions, outcomes assessed and the inconsistency in the findings resulted in an insufficient SOE.

#### Changes in Appetite

Two fair-quality RCTs did not report statistical significance of the proportion of patients in each study arm who reported changes in appetite associated with two doses of zinc supplementation compared with placebo,^111^ or an herbal preparation compared with placebo.^140^ Given the variability in interventions, the small number of patients in each study experiencing the outcome, and differential loss to followup resulted in insufficient SOE.

#### Changes in Standardized Symptom Scores

Four RCTs reported changes in symptom scores. One demonstrated improvement in ADHD-RS scores associated with an elimination diet relative to a nonrestricted diet.^172^ The other three RCTs found that neither Memomet syrup nor zinc supplementation nor vitamin D improved ADHD symptoms compared with placebo (low SOE).^111, 125, 144^

#### Gastrointestinal Symptoms

Two RCTs did not report statistical significance of the proportion of patients in each study arm who reported stomach aches or other gastrointestinal symptoms associated with two doses of zinc supplementation^111^ or herbal preparation^140^ compared with placebo. The variability in interventions, outcomes assessed and the loss to followup resulted in insufficient SOE.

#### Adverse Effects of Herbal Interventions or Dietary Approaches

An RCT that evaluated two doses of zinc supplementation compared with placebo^111^ did not report statistical significance in the difference in proportion of patients in each study arm who reported changes in appetite, stomach aches or other gastrointestinal symptoms, sleep disturbance, harm to self or others, or stereotypical behaviors. Another RCT found no between-group differences between an herbal preparation and placebo in gastrointestinal symptoms, emotional lability, accidental injury, or sleep disturbance.^140^ The SOE was considered insufficient because identified studies varied in the interventions and outcomes assessed and had differential loss to follow up.

### Strength of Evidence—Herbal Interventions or Dietary Approaches

Table 18 summarizes the SOE for herbal interventions or dietary approaches based on this report’s included studies. Small numbers of studies with imprecise findings caused insufficient SOe grades for all outcomes other than changes in standardized symptom scores.

Table 18 Strength of evidence for major outcomes—herbal interventions or dietary approaches

Outcome SOE Grade | No. Studies/Design (N Patients) Age Category | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Findings
Behavior changes Insufficient | 3 RCTs (172) All through 17 | Low | Direct | Inconsistent | Imprecise | None | The SOE was considered insufficient because identified studies varied in intervention and outcomes assessed and then demonstrated inconsistent findings.^158^ ^111, 144^
Changes in appetite Insufficient | 2 RCTs (172) 7–17 | Medium | Direct | Consistent | Imprecise | None | The SOE was considered insufficient given the variability in interventions, the small number of patients in each study experiencing the outcome, and differential loss to followup..^111, 140^
Changes in standardized symptom scores Low | 4 RCTs (292) 7–17, all through 17 | Low | Direct | Inconsistent | Imprecise | None | An elimination diet improved ADHD-RS scores relative to a non-restricted diet,^172^ but did not find a reduction in ADHD symptoms relative to placebo for either Memomet syrup or zinc supplementation.^111, 125, 144^
Gastrointestinal symptoms Insufficient | 2 RCTs (172) 7–17 | Medium | Direct | Inconsistent | Imprecise | None | The SOE was considered insufficient because identified studies varied in the interventions and outcomes assessed and had differential loss to follow up^111, 140^
Mood disorders Insufficient | 1 RCT (120) 7–17 | Medium | Direct | NA | Imprecise | None | The SOE was considered insufficient because only one study was identified which had imprecise findings and differential loss to follow up..^140^
Motor vehicle collisions Insufficient | 1 RCT (120) 7–17 | Medium | Direct | NA | Imprecise | None | The SOE was considered insufficient because only one small study was identified.^140^
Sleep disturbance Insufficient | 2 RCTs (172) 7–17 | Medium | Direct | Consistent | Imprecise | None | The SOE was considered insufficient because identified studies varied in the interventions and outcomes assessed and had differential loss to follow up^111, 140^}
Suicide ideation Insufficient | 1 RCT (52) 7–17 | Medium | Direct | NA | Imprecise | None | The SOE was considered insufficient because only one small study was identified.^111^
Tics or other movement disorders Insufficient | 1 RCT (52) 7–17 | Medium | Direct | NA | Imprecise | None | The SOE was considered insufficient because only one small study was identified.^111^

Abbreviations: NA=not applicable; Obs=observational; RCT=randomized controlled trial; SOE=strength of evidence

### Detailed Synthesis—Other Approaches

One good-quality^107^ and 8 fair-quality studies^128, 137, 145, 149, 153, 170, 171, 175^ representing 1,286 enrolled patients evaluated other approaches. These studies looked at a range of programs including community programs and programs that addressed mentoring and parent support,^128^ multisystemic intervention at school and with parents,^153, 170^ in-home family training intervention,^107^ a general parenting program,^175^ using melatonin as an adjunct treatment, acupuncture, and a homeopathic intervention. This diverse range of interventions share some features with other interventions with several having parent components,^107, 128, 153, 170, 175^ but each were different from typical parent focused interventions in that there were other major components or they were generic parenting programs. Findings are summarized by outcome and described in Table H-13 in Appendix H. Neither the Challenging Horizons Program – after school version nor the Family School Success – Early Elementary Program improved academic performance (SOE=low). The SOE was insufficient for all other outcomes for each of the interventions considered.

### Findings in Relation to What Is Already Known—Other Approaches

The 2011 report^4^ identified 7 studies that examined multiple component psychosocial and/or behavioral interventions for preschool children with disruptive behavior disorder. Of these, five RCTs included only preschoolers who exhibited ADHD symptoms but who were not necessarily formally diagnosed with ADHD.^211–215^ All five of these RCTs demonstrated significant improvement in the preschoolers’ behavior or symptoms relative to their comparison groups, most of which were usual care only. In contrast, this updated review provides results from two RCTs that examined a multiple component intervention for children specifically diagnosed with ADHD that included both school and parent components.^153, 170^ Findings of these two studies are summarized by outcome and described in Table H-13 in Appendix H. Despite the support for behavioral interventions from the 2011 report, this report found insufficient SOE to evaluate the impact of these interventions on ADHD symptoms. In part, this is because we only included studies where children received formal diagnosis of ADHD.

### Strength of Evidence—Other Approaches

Table 19 summarizes the SOE for other approaches based on this report’s included studies. Small numbers of studies with imprecise findings caused insufficient SOE grades for all outcomes other than academic performance.

Table 19 Strength of evidence for major outcomes—other approaches

Outcome SOE Grade | No. Studies/Design (N Patients) Age Category | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Findings
Academic performance Low | 3 RCTs (586) 7–17, all through 17 | Medium | Direct | Consistent | Imprecise | None | Neither the Challenging Horizons Program (After School version) nor the Family School Success (Early Elementary) interventions were found to improve academic performance in 3 fair-quality RCTs.^128, 153, 170^
Behavior changes Insufficient | 4 RCTs (508) 6 and under, 7–17, all through 17 | Medium | Direct | Consistent | Imprecise | Suspect (given dropout and lack of clarity in reporting findings) | The SOE was considered insufficient because of concerns about risk of reporting bias and lack of precision in study results. ^107, 145, 149, 171^ ^188^
Changes in appetite Insufficient | 1 RCT (60) 7–17 | Medium | Direct | NA | Imprecise | None | The SOE was considered insufficient because only one small study was identified.^145, 188^
Changes in standardized symptom scores Insufficient | 3 RCTs (252) 7–17, all through 17 | Medium | Direct | Consistent | Imprecise | None | The SOE was considered insufficient because of lack of precision across the 3 fair-quality studies with varying mean changes between different standardized scores.^137, 145, 175, 188^
Functional impairment Insufficient | 1 RCT (326) 7–17 | Medium | Direct | NA | Imprecise | None | The SOE was considered insufficient because only one small study was identified.^128^
Gastrointestinal symptoms Insufficient | 1 RCT (60) 7–17 | Medium | Direct | NA | Imprecise | None | The SOE was considered insufficient because only one small study was identified.^145, 188^
Sleep disturbance Insufficient | 1 RCTs (60) 7–17 | Medium | Direct | NA | Imprecise | None | The SOE was considered insufficient because only one small study was identified.^145, 188^
Tics or other movement disorders Insufficient | 1 RCT (60) 7–17 | Medium | Direct | NA | Imprecise | None | The SOE was considered insufficient because only one small study was identified.^145, 188^
Weight decrease Insufficient | 1 RCT (60) 7–17 | Medium | Direct | NA | Imprecise | None | The SOE was considered insufficient because only one small study was identified.^145, 188^

Abbreviations: NA=not applicable; Obs=observational; RCT=randomized controlled trial; SOE=strength of evidence

## Key Question 3 ADHD Monitoring

KQ 3 examined the comparative safety and effectiveness of different monitoring strategies to evaluate the effectiveness of treatment or changes in ADHD status (e.g., worsening or resolving symptoms). We did not identify any studies that met criteria for inclusion for KQ 3.