# References

1 Centers for Disease Control and Prevention. Attention-Deficit/Hyperactivity Disorder (ADHD). Data & Statistics. www.cdc.gov/ncbddd/adhd/data.html. Accessed April 3, 2015.
2 Akinbami LJ, Liu X, Pastor PN, . Attention deficit hyperactivity disorder among children aged 5–17 years in the United States, 1998–2009. NCHS data brief, no 70. Hyattsville, MD: National Center for Health Statistics. 2011. www.cdc.gov/nchs/data/databriefs/db70.htm#citation. Accessed April 3, 2015.
3 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 5th ed. Arlington, VA: American Psychiatric Publishing; 2013.
4 Charach A, Dashti B, Carson P, . Attention Deficit Hyperactivity Disorder: Effectiveness of Treatment in At-Risk Preschoolers; Long-Term Effectiveness in All Ages; and Variability in Prevalence, Diagnosis, and Treatment. Comparative Effectiveness Review No. 44. (Prepared by the McMaster University Evidence-based Practice Center under Contract No. MME2202 290-02-0020.) AHRQ Publication No. 12-EHC003-EF. Rockville, MD: Agency for Healthcare Research and Quality. October 2011. http://www.effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=814. Accessed July 16, 2015.
5 Arnett AB, Pennington BF, Willcutt EG, . Sex differences in ADHD symptom severity. J Child Psychol Psychiatry. 2015 Jun;56(6):632–9. doi: 10.1111/jcpp.12337. PMID: 25283790.25283790
6 Galera C, Cote SM, Bouvard MP, . Early risk factors for hyperactivity-impulsivity and inattention trajectories from age 17 months to 8 years. Arch Gen Psychiatry. 2011 Dec;68(12):1267–75. doi: 10.1001/archgenpsychiatry.2011.138. PMID: 22147844.22147844
7 Leslie LK, Weckerly J, Plemmons D, . Implementing the American Academy of Pediatrics attention-deficit/hyperactivity disorder diagnostic guidelines in primary care settings. Pediatrics. 2004 Jul;114(1):129–40. PMID: 15231919.15231919
8 U.S. Food and Drug Administration. Neuropsychiatric Electroencephalograph-Based Assessment Aid (NEBA). http://www.accessdata.fda.gov/cdrh_docs/reviews/K112711.pdf. Accessed October 19, 2015.
9 Wiener J, Malone M, Varma A, . Children’s perceptions of their ADHD symptoms: positive illusions, attributions, and stigma. Canadian Journal of School Psychology. 2012 September 1, 2012;27(3):217–42. doi: 10.1177/0829573512451972.
10 Lebowitz MS. Stigmatization of ADHD: a developmental review. J Atten Disord. 2013 February 13, 2013doi: 10.1177/1087054712475211.
11 Cook J, Knight E, Hume I, . The self-esteem of adults diagnosed with attention-deficit/hyperactivity disorder (ADHD): a systematic review of the literature. Atten Defic Hyperact Disord. 2014 2014/12/01;6(4):249–68. doi: 10.1007/s12402-014-0133-2.24668198
12 Subcommittee on Attention-Deficit/Hyperactivity Disorder. Steering Committee on Quality Improvement Management. ADHD: Clinical Practice Guideline for the Diagnosis, Evaluation, and Treatment of Attention-Deficit/Hyperactivity Disorder in Children and Adolescents. Pediatrics. 2011 October 16, 2011doi: 10.1542/peds.2011-2654.
13 Vitiello B. Understanding the risk of using medications for attention deficit hyperactivity disorder with respect to physical growth and cardiovascular function. Child Adolesc Psychiatr Clin N Am. 2008 Apr;17(2):459–74, xi. doi: 10.1016/j.chc.2007.11.010. PMID: 18295156.18295156
14 Chen LY, Crum RM, Martins SS, . Patterns of concurrent substance use among nonmedical ADHD stimulant users: results from the National Survey on Drug Use and Health. Drug Alcohol Depend. 2014 Sep 1;142:86–90. doi: 10.1016/j.drugalcdep.2014.05.022. PMID: 24957742.24957742
15 Bussing R, Fernandez M, Harwood M, . Parent and teacher SNAP-IV ratings of attention deficit hyperactivity disorder symptoms: psychometric properties and normative ratings from a school district sample. Assessment. 2008 Sep;15(3):317–28. doi: 10.1177/1073191107313888. PMID: 18310593.18310593
16 Conners CK, Pitkanen J, Rzepa S. Conners Comprehensive Behavior Rating Scale. In: Kreutzer J, DeLuca J, Caplan B, eds. Encyclopedia of Clinical Neuropsychology. Springer New York; 2011:678–80.
17 Bard DE, Wolraich ML, Neas B, . The psychometric properties of the Vanderbilt Attention-Deficit Hyperactivity Disorder Diagnostic Parent Rating Scale in a community population. Journal of Developmental & Behavioral Pediatrics. 2013;34(2):72–82. doi: 10.1097/DBP.0b013e31827a3a22. PMID: 23363973.23363972
18 Fiks AG, Mayne S, DeBartolo E, . Parental preferences and goals regarding ADHD treatment. Pediatrics. 2013 October 1, 2013;132(4):692–702. doi: 10.1542/peds.2013-0152.23999959
19 Jadad AR, Boyle M, Cunningham C, . Treatment of attention-deficit/hyperactivity disorder. Evid Rep Technol Assess (Summ). 1999 Nov(11):i–viii, 1–341. PMID: 10790990.10790990
20 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD: Agency for Healthcare Research and Quality. http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. Accessed July 16, 2015.
21 Moher D, Liberati A, Tetzlaff J, . Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. 2009 Jul 21;6(7):e1000097. doi: 10.1371/journal.pmed.1000097. PMID: 19621072.19621072
22 Cohen SC, Mulqueen JM, Ferracioli-Oda E, . Meta-Analysis: Risk of Tics Associated With Psychostimulant Use in Randomized, Placebo-Controlled Trials. J Am Acad Child Adolesc Psychiatry. 2015 Sep;54(9):728–36. doi: 10.1016/j.jaac.2015.06.011. PMID: 26299294.26299294
23 Buitelaar J, Asherson P, Soutullo C, . Differences in maintenance of response upon discontinuation across medication treatments in attention-deficit/hyperactivity disorder. Eur Neuropsychopharmacol. 2015 Oct;25(10):1611–21. doi: 10.1016/j.euroneuro.2015.06.003. PMID: 26169574.26169574
24 Richardson M, Moore DA, Gwernan-Jones R, . Non-pharmacological interventions for attention-deficit/hyperactivity disorder (ADHD) delivered in school settings: systematic reviews of quantitative and qualitative research. Health Technol Assess. 2015 Jun;19(45):1–470. doi: 10.3310/hta19450. PMID: 26129788.26129788
25 Martinez-Raga J, Knecht C, de Alvaro R. Profile of guanfacine extended release and its potential in the treatment of attention-deficit hyperactivity disorder. Neuropsychiatr Dis Treat. 2015;11:1359–70. doi: 10.1155/2015/982072. PMID: 26064054.26064054
26 Maneeton B, Maneeton N, Likhitsathian S, . Comparative efficacy, acceptability, and tolerability of lisdexamfetamine in child and adolescent ADHD: a meta-analysis of randomized, controlled trials. Drug Des Devel Ther. 2015;9:1927–36. doi: 10.2147/dddt.s79071. PMID: 25897203.25897203
27 Pringsheim T, Hirsch L, Gardner D, . The Pharmacological Management of Oppositional Behaviour, Conduct Problems, and Aggression in Children and Adolescents With Attention-Deficit Hyperactivity Disorder, Oppositional Defiant Disorder, and Conduct Disorder: A Systematic Review and Meta-Analysis. Part 1: Psychostimulants, Alpha-2 Agonists, and Atomoxetine. Can J Psychiatry. 2015 Feb 1;60(2):42–51. PMID: 25886655.25886655
28 Stuhec M, Munda B, Svab V, . Comparative efficacy and acceptability of atomoxetine, lisdexamfetamine, bupropion and methylphenidate in treatment of attention deficit hyperactivity disorder in children and adolescents: a meta-analysis with focus on bupropion. J Affect Disord. 2015 Jun 1;178:149–59. doi: 10.1016/j.jad.2015.03.006. PMID: 25813457.25813457
29 Rizzo R, Martino D. Guanfacine for the treatment of attention deficit hyperactivity disorder in children and adolescents. Expert Rev Neurother. 2015 Apr;15(4):347–54. doi: 10.1586/14737175.2015.1028370. PMID: 25800130.25800130
30 Spencer-Smith M, Klingberg T. Benefits of a working memory training program for inattention in daily life: a systematic review and meta-analysis. PLoS One. 2015;10(3):e0119522. doi: 10.1371/journal.pone.0119522. PMID: 25793607.25793607
31 Garcia Murillo L, Cortese S, Anderson D, . Locomotor activity measures in the diagnosis of attention deficit hyperactivity disorder: Meta-analyses and new findings. J Neurosci Methods. 2015 Aug 30;252:14–26. doi: 10.1016/j.jneumeth.2015.03.001. PMID: 25770940.25770940
32 Cortese S, Ferrin M, Brandeis D, . Cognitive training for attention-deficit/hyperactivity disorder: meta-analysis of clinical and neuropsychological outcomes from randomized controlled trials. J Am Acad Child Adolesc Psychiatry. 2015 Mar;54(3):164–74. doi: 10.1016/j.jaac.2014.12.010. PMID: 25721181.25721181
33 Micoulaud-Franchi JA, Geoffroy PA, Fond G, . EEG neurofeedback treatments in children with ADHD: an updated meta-analysis of randomized controlled trials. Front Hum Neurosci. 2014;8:906. doi: 10.3389/fnhum.2014.00906. PMID: 25431555.25431555
34 Maneeton N, Maneeton B, Intaprasert S, . A systematic review of randomized controlled trials of bupropion versus methylphenidate in the treatment of attention-deficit/hyperactivity disorder. Neuropsychiatr Dis Treat. 2014;10:1439–49. doi: 10.2147/ndt.s62714. PMID: 25120365.25120365
35 Daley D, van der Oord S, Ferrin M, . Behavioral interventions in attention-deficit/hyperactivity disorder: a meta-analysis of randomized controlled trials across multiple outcome domains. J Am Acad Child Adolesc Psychiatry. 2014 Aug;53(8):835–47, 47.e1–5. doi: 10.1016/j.jaac.2014.05.013. PMID: 25062591.25062591
36 Schoenfelder EN, Faraone SV, Kollins SH. Stimulant treatment of ADHD and cigarette smoking: a meta-analysis. Pediatrics. 2014 Jun;133(6):1070–80. doi: 10.1542/peds.2014-0179. PMID: 24819571.24819571
37 Coghill DR, Caballero B, Sorooshian S, . A systematic review of the safety of lisdexamfetamine dimesylate. CNS Drugs. 2014 Jun;28(6):497–511. doi: 10.1007/s40263-014-0166-2. PMID: 24788672.24788672
38 Bagot KS, Kaminer Y. Efficacy of stimulants for cognitive enhancement in non-attention deficit hyperactivity disorder youth: a systematic review. Addiction. 2014 Apr;109(4):547–57. PMID: 24749160.24749160
39 Puri BK, Martins JG. Which polyunsaturated fatty acids are active in children with attention-deficit hyperactivity disorder receiving PUFA supplementation? A fatty acid validated meta-regression analysis of randomized controlled trials. Prostaglandins Leukot Essent Fatty Acids. 2014 May;90(5):179–89. doi: 10.1016/j.plefa.2014.01.004. PMID: 24560325.24560325
40 Findling RL, Dinh S. Transdermal therapy for attention-deficit hyperactivity disorder with the methylphenidate patch (MTS). CNS Drugs. 2014 Mar;28(3):217–28. doi: 10.1007/s40263-014-0141-y. PMID: 24532028.24532028
41 Schwartz S, Correll CU. Efficacy and safety of atomoxetine in children and adolescents with attention-deficit/hyperactivity disorder: results from a comprehensive meta-analysis and metaregression. J Am Acad Child Adolesc Psychiatry. 2014 Feb;53(2):174–87. doi: 10.1016/j.jaac.2013.11.005. PMID: 24472252.24472252
42 Barrett JR, Tracy DK, Giaroli G. To sleep or not to sleep: a systematic review of the literature of pharmacological treatments of insomnia in children and adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2013 Dec;23(10):640–7. doi: 10.1089/cap.2013.0059. PMID: 24261659.24261659
43 Park P, Caballero J, Omidian H. Use of serotonin norepinephrine reuptake inhibitors in the treatment of attention-deficit hyperactivity disorder in pediatrics. Ann Pharmacother. 2014 Jan;48(1):86–92. doi: 10.1177/1060028013506561. PMID: 24259607.24259607
44 Rapport MD, Orban SA, Kofler MJ, . Do programs designed to train working memory, other executive functions, and attention benefit children with ADHD? A meta-analytic review of cognitive, academic, and behavioral outcomes. Clin Psychol Rev. 2013 Dec;33(8):1237–52. doi: 10.1016/j.cpr.2013.08.005. PMID: 24120258.24120258
45 von Sydow K, Retzlaff R, Beher S, . The efficacy of systemic therapy for childhood and adolescent externalizing disorders: a systematic review of 47 RCT. Fam Process. 2013 Dec;52(4):576–618. doi: 10.1111/famp.12047. PMID: 24102196.24102196
46 Mulqueen JM, Bartley CA, Bloch MH. Meta-analysis: parental interventions for preschool ADHD. J Atten Disord. 2015 Feb;19(2):118–24. doi: 10.1177/1087054713504135. PMID: 24071773.24071773
47 Cassone AR. Mindfulness training as an adjunct to evidence-based treatment for ADHD within families. J Atten Disord. 2015 Feb;19(2):147–57. doi: 10.1177/1087054713488438. PMID: 23704114.23704114
48 Chacko A, Feirsen N, Bedard AC, . Cogmed Working Memory Training for youth with ADHD: a closer examination of efficacy utilizing evidence-based criteria. J Clin Child Adolesc Psychol. 2013;42(6):769–83. doi: 10.1080/15374416.2013.787622. PMID: 23668397.23668397
49 Reichow B, Volkmar FR, Bloch MH. Systematic review and meta-analysis of pharmacological treatment of the symptoms of attention-deficit/hyperactivity disorder in children with pervasive developmental disorders. J Autism Dev Disord. 2013 Oct;43(10):2435–41. doi: 10.1007/s10803-013-1793-z. PMID: 23468071.23468071
50 Sonuga-Barke EJ, Brandeis D, Cortese S, . Nonpharmacological interventions for ADHD: systematic review and meta-analyses of randomized controlled trials of dietary and psychological treatments. Am J Psychiatry. 2013 Mar;170(3):275–89. doi: 10.1176/appi.ajp.2012.12070991. PMID: 23360949.23360949
51 Lofthouse N, Arnold LE, Hurt E. Current status of neurofeedback for attention-deficit/hyperactivity disorder. Curr Psychiatry Rep. 2012 Oct;14(5):536–42. doi: 10.1007/s11920-012-0301-z. PMID: 22890816.22890816
52 Hanwella R, Senanayake M, de Silva V. Comparative efficacy and acceptability of methylphenidate and atomoxetine in treatment of attention deficit hyperactivity disorder in children and adolescents: a meta-analysis. BMC Psychiatry. 2011;11:176. doi: 10.1186/1471-244x-11-176. PMID: 22074258.22074258
53 Berek M, Kordon A, Hargarter L, . Improved functionality, health related quality of life and decreased burden of disease in patients with ADHD treated with OROS(R) MPH: is treatment response different between children and adolescents? Child Adolesc Psychiatry Ment Health. 2011;5:26. doi: 10.1186/1753-2000-5-26. PMID: 21791096.21791096
54 Ming X, Mulvey M, Mohanty S, . Safety and efficacy of clonidine and clonidine extended-release in the treatment of children and adolescents with attention deficit and hyperactivity disorders. Adolesc Health Med Ther. 2011;2:105–12. doi: 10.2147/ahmt.s15672. PMID: 24600280.24600280
55 Elbe D, Macbride A, Reddy D. Focus on Lisdexamfetamine: A Review of its use in Child and Adolescent Psychiatry. J Can Acad Child Adolesc Psychiatry. 2010 Nov;19(4):303–14. PMID: 21037922.21037922
56 Coghill D. The impact of medications on quality of life in attention-deficit hyperactivity disorder: a systematic review. CNS Drugs. 2010 Oct;24(10):843–66. doi: 10.2165/11537450-000000000-00000. PMID: 20839896.20839896
57 Battagliese G, Caccetta M, Luppino OI, . Cognitive-behavioral therapy for externalizing disorders: A meta-analysis of treatment effectiveness. Behav Res Ther. 2015;75:60–71.26575979
58 Pringsheim T, Hirsch L, Gardner D, . The pharmacological management of oppositional behaviour, conduct problems, and Aggression in children and adolescents with Attention-deficit hyperactivity disorder, oppositional defiant disorder, and conduct disorder: A systematic review and meta-analysis. Part 2: Antipsychotics and traditional mood stabilizers. Can J Psychiatry. 2015;60(2):52–61.25886656
59 Grassmann V, Santos-Galduróz RF, Galduróz JCF. Effects of low doses of polyunsaturated fatty acids on the attention deficit/Hyperactivity disorder of children: A systematic review. Current Neuropharmacology. 2013;11(2):186–96.23997753
60 Karch D, Albers L, Renner G, . The efficacy of cognitive training programs in children and adolescents. Deutsches Arzteblatt International. 2013;110(39):643–52.24163706
61 Tarver J, Daley D, Lockwood J, . Are self-directed parenting interventions sufficient for externalising behaviour problems in childhood? A systematic review and meta-analysis. European Child & Adolescent Psychiatry. 2014;23(12):1123–37. doi: 10.1007/s00787-014-0556-5. PMID: 2014-21110-001.24842197
62 Nigg JT, Holton K. Restriction and elimination diets in ADHD treatment. Child and Adolescent Psychiatric Clinics of North America. 2014;23(4):937–53. doi: 10.1016/j.chc.2014.05.010. PMID: 2014-33672-001.25220094
63 Hurt EA, Arnold LE. An integrated dietary/nutritional approach to ADHD. Child and Adolescent Psychiatric Clinics of North America. 2014;23(4):955–64. doi: 10.1016/j.chc.2014.06.002. PMID: 2014-33671-001.25220095
64 Maneeton N, Maneeton B, Intaprasert S, . Asystematic review of randomized controlled trials of bupropion versus methylphenidate in the treatment of attention-deficit/hyperactivity disorder. Neuropsychiatr Dis Treat. 2014;10 PMID: 2014-34728-001.
65 Storebo OJ, Krogh HB, Ramstad E, . Methylphenidate for attention-deficit/hyperactivity disorder in children and adolescents: Cochrane systematic review with meta-analyses and trial sequential analyses of randomised clinical trials. BMJ. 2015;351:h5203. doi: 10.1136/bmj.h5203. PMID: 26608309.26608309
66 Rezaei G, Hosseini SA, Akbari Sari A, . Comparative efficacy of methylphenidate and atomoxetine in the treatment of attention deficit hyperactivity disorder in children and adolescents: A systematic review and meta-analysis. Med J Islam Repub Iran. 2016;30:325. PMID: 27390695.27390695
67 Reed VA, Buitelaar JK, Anand E, . The Safety of Atomoxetine for the Treatment of Children and Adolescents with Attention-Deficit/Hyperactivity Disorder: A Comprehensive Review of Over a Decade of Research. CNS Drugs. 2016 Jul;30(7):603–28. doi: 10.1007/s40263-016-0349-0. PMID: 27290715.27290715
68 Cortese S, Ferrin M, Brandeis D, . Neurofeedback for Attention-Deficit/Hyperactivity Disorder: Meta-Analysis of Clinical and Neuropsychological Outcomes From Randomized Controlled Trials. J Am Acad Child Adolesc Psychiatry. 2016 Jun;55(6):444–55. doi: 10.1016/j.jaac.2016.03.007. PMID: 27238063.27238063
69 Rimestad ML, Lambek R, Zacher Christiansen H, . Short- and Long-Term Effects of Parent Training for Preschool Children With or at Risk of ADHD: A Systematic Review and Meta-Analysis. J Atten Disord. 2016 May 14doi: 10.1177/1087054716648775. PMID: 27179355.27179355
70 Chan E, Fogler JM, Hammerness PG. Treatment of Attention-Deficit/Hyperactivity Disorder in Adolescents: A Systematic Review. JAMA. 2016 May 10;315(18):1997–2008. doi: 10.1001/jama.2016.5453. PMID: 27163988.27163988
71 Tamminga HG, Reneman L, Huizenga HM, . Effects of methylphenidate on executive functioning in attention-deficit/hyperactivity disorder across the lifespan: a meta-regression analysis. Psychol Med. 2016 Jul;46(9):1791–807. doi: 10.1017/s0033291716000350. PMID: 27019103.27019103
72 Millichap JG. Risk of Tics with Psychostimulants for ADHD. Pediatr Neurol Briefs. 2015 Dec;29(12):95. doi: 10.15844/pedneurbriefs-29-12-6. PMID: 26933551.26933551
73 Chang LY, Wang MY, Tsai PS. Diagnostic Accuracy of Rating Scales for Attention-Deficit/Hyperactivity Disorder: A Meta-analysis. Pediatrics. 2016 Mar;137(3):e20152749. doi: 10.1542/peds.2015-2749. PMID: 26928969.26928969
74 Punja S, Shamseer L, Hartling L, . Amphetamines for attention deficit hyperactivity disorder (ADHD) in children and adolescents. Cochrane Database Syst Rev. 2016;2:Cd009996. doi: 10.1002/14651858.CD009996.pub2. PMID: 26844979.26844979
75 Maneeton N, Maneeton B, Woottiluk P, . Comparative efficacy, acceptability, and tolerability of dexmethylphenidate versus placebo in child and adolescent ADHD: a meta-analysis of randomized controlled trials. Neuropsychiatr Dis Treat. 2015;11:2943–52. doi: 10.2147/ndt.s91765. PMID: 26648726.26648726
76 Hall CL, Valentine AZ, Groom MJ, . The clinical utility of the continuous performance test and objective measures of activity for diagnosing and monitoring ADHD in children: a systematic review. Eur Child Adolesc Psychiatry. 2016 Jul;25(7):677–99. doi: 10.1007/s00787-015-0798-x. PMID: 26620873.26620873
77 Storebo OJ, Ramstad E, Krogh HB, . Methylphenidate for children and adolescents with attention deficit hyperactivity disorder (ADHD). Cochrane Database Syst Rev. 2015(11):Cd009885. doi: 10.1002/14651858.CD009885.pub2. PMID: 26599576.26599576
78 Kidwell KM, Van Dyk TR, Lundahl A, . Stimulant Medications and Sleep for Youth With ADHD: A Meta-analysis. Pediatrics. 2015 Dec;136(6):1144–53. doi: 10.1542/peds.2015-1708. PMID: 26598454.26598454
79 Epstein T, Patsopoulos NA, Weiser M. Immediate-release methylphenidate for attention deficit hyperactivity disorder (ADHD) in adults. Cochrane Database of Systematic Reviews. 2016;2016(5).
80 U.S. Food and Drug Administration. Information about Medications Used to Treat Attention-Deficit/Hyperactivity Disorder (ADHD). http://www.fda.gov/Drugs/DrugSafety/InformationbyDrugClass/ucm283449.htm. Accessed August 26, 2016.
81 Agency for Healthcare Research and Quality. Systematic Review Data Repository. http://srdr.ahrq.gov/. Accessed January 29, 2016.
82 Higgins JPT, Green S. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0 [updated March 2011]. www.cochrane-handbook.org: The Cochrane Collaboration; 2011.
83 Wells GA, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Ottawa, Canada. Ottawa Hospital Research Institute. Available at www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed July 16, 2015.
84 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD); 2013.
85 Atkins D, Chang SM, Gartlehner G, . Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011 Nov;64(11):1198–207. doi: 10.1016/j.jclinepi.2010.11.021. PMID: 21463926.21463926
86 Bunte TL, Schoemaker K, Hessen DJ, . Clinical usefulness of the Kiddie-Disruptive Behavior Disorder Schedule in the diagnosis of DBD and ADHD in preschool children. J Abnorm Child Psychol. 2013 Jul;41(5):681–90. doi: 10.1007/s10802-013-9732-1. PMID: 23474833.23474833
87 Thorell LB, Eninger L, Brocki KC, . Childhood executive function inventory (CHEXI): a promising measure for identifying young children with ADHD? J Clin Exp Neuropsychol. 2010 Jan;32(1):38–43. doi: 10.1080/13803390902806527. PMID: 19381995.19381995
88 Berger I, Goldzweig G. Objective measures of attention-deficit/hyperactivity disorder: a pilot study. Isr Med Assoc J. 2010 Sep;12(9):531–5. PMID: 21287795.21287795
89 Bloch Y, Fixman M, Maoz H, . Can computerized cognitive tests assist in the clinical diagnosis of attention-deficit hyperactivity disorder? J Neuropsychiatry Clin Neurosci. 2012 Winter;24(1):111–4. doi: 10.1176/appi.neuropsych.11010014. PMID: 22450621.22450621
90 dosReis S, Barksdale CL, Sherman A, . Stigmatizing experiences of parents of children with a new diagnosis of ADHD. Psychiatric Services. 2010;61(8):811–6. doi: 10.1176/appi.ps.61.8.811. PMID: 2010-16657-009.20675840
91 Ferrin M, Vance A. Examination of neurological subtle signs in ADHD as a clinical tool for the diagnosis and their relationship to spatial working memory. J Child Psychol Psychiatry. 2012 Apr;53(4):390–400. doi: 10.1111/j.1469-7610.2011.02496.x. PMID: 22141455.22141455
92 Kim JW, Lee J, Kim BN, . Theta-phase gamma-amplitude coupling as a neurophysiological marker of attention deficit/hyperactivity disorder in children. Neurosci Lett. 2015 Aug 31;603:25–30. doi: 10.1016/j.neulet.2015.07.006. PMID: 26170246.26170246
93 Kim J, Lee Y, Han D, . The utility of quantitative electroencephalography and Integrated Visual and Auditory Continuous Performance Test as auxiliary tools for the Attention Deficit Hyperactivity Disorder diagnosis. Clin Neurophysiol. 2015 Mar;126(3):532–40. doi: 10.1016/j.clinph.2014.06.034. PMID: 25088931.25088931
94 Klenberg L, Jamsa S, Hayrinen T, . The Attention and Executive Function Rating Inventory (ATTEX): Psychometric properties and clinical utility in diagnosing ADHD subtypes. Scand J Psychol. 2010 Mar 19;51(5):439–48. doi: 10.1111/j.1467-9450.2010.00812.x. PMID: 20338019.20338019
95 Liechti MD, Valko L, Muller UC, . Diagnostic value of resting electroencephalogram in attention-deficit/hyperactivity disorder across the lifespan. Brain Topogr. 2013 Jan;26(1):135–51. doi: 10.1007/s10548-012-0258-6. PMID: 23053601.23053601
96 Markovska-Simoska S, Pop-Jordanova N. Quantitative EEG in Children and Adults With Attention Deficit Hyperactivity Disorder: Comparison of Absolute and Relative Power Spectra and Theta/Beta Ratio. Clin EEG Neurosci. 2016 May 11doi: 10.1177/1550059416643824. PMID: 27170672.27170672
97 Martin-Martinez D, Casaseca-de-la-Higuera P, Alberola-Lopez S, . Nonlinear analysis of actigraphic signals for the assessment of the attention-deficit/hyperactivity disorder (ADHD). Med Eng Phys. 2012 Nov;34(9):1317–29. doi: 10.1016/j.medengphy.2011.12.023. PMID: 22297088.22297088
98 Ogrim G, Kropotov J, Hestad K. The quantitative EEG theta/beta ratio in attention deficit/hyperactivity disorder and normal controls: sensitivity, specificity, and behavioral correlates. Psychiatry Res. 2012 Aug 15;198(3):482–8. doi: 10.1016/j.psychres.2011.12.041. PMID: 22425468.22425468
99 Ohan JL, Visser TAW, Strain MC, . Teachers’ and education students’ perceptions of and reactions to children with and without the diagnostic label ‘ADHD’. Journal of School Psychology. 2011;49(1):81–105. doi: 10.1016/j.jsp.2010.10.001. PMID: 2011-00464-004.21215837
100 Park J, Kim C, Ahn JH, . Clinical Use of Continuous Performance Tests to Diagnose Children With ADHD. J Atten Disord. 2016 Jul 12doi: 10.1177/1087054716658125. PMID: 27412120.27412120
101 Soliva JC, Fauquet J, Bielsa A, . Quantitative MR analysis of caudate abnormalities in pediatric ADHD: proposal for a diagnostic test. Psychiatry Res. 2010 Jun 30;182(3):238–43. doi: 10.1016/j.pscychresns.2010.01.013. PMID: 20488672.20488672
102 Zelnik N, Bennett-Back O, Miari W, . Is the test of variables of attention reliable for the diagnosis of attention-deficit hyperactivity disorder (ADHD)? J Child Neurol. 2012 Jun;27(6):703–7. doi: 10.1177/0883073811423821. PMID: 22378668.22378668
103 Carballo JJ, Rodriguez-Blanco L, Garcia-Nieto R, . Screening for the ADHD Phenotype Using the Strengths and Difficulties Questionnaire in a Clinical Sample of Newly Referred Children and Adolescents. J Atten Disord. 2014 Dec 16doi: 10.1177/1087054714561858. PMID: 25515677.25515677
104 Castro-Cabrera P, Gomez-Garcia J, Restrepo F, . Evaluation of feature extraction techniques on event-related potentials for detection of attention-deficit/hyperactivity disorder. Conf Proc IEEE Eng Med Biol Soc. 2010;2010:851–4. doi: 10.1109/iembs.2010.5626862. PMID: 21096317.21096317
105 Caudal F. New marker using bioimpedance technology in screening for attention deficit/hyperactivity disorder (ADHD) in children as an adjunct to conventional diagnostic methods. Psychol Res Behav Manag. 2011;4:113–7. doi: 10.2147/prbm.s22924. PMID: 22114541.22114541
106 Gonzalez JJ, Mendez LD, Manas S, . Performance analysis of univariate and multivariate EEG measurements in the diagnosis of ADHD. Clin Neurophysiol. 2013 Jun;124(6):1139–50. doi: 10.1016/j.clinph.2012.12.006. PMID: 23332776.23332776
107 Abikoff HB, Thompson M, Laver-Bradbury C, . Parent training for preschool ADHD: a randomized controlled trial of specialized and generic programs. J Child Psychol Psychiatry. 2015 Jun;56(6):618–31. doi: 10.1111/jcpp.12346. PMID: 25318650.25318650
108 Abikoff H, Gallagher R, Wells KC, . Remediating organizational functioning in children with ADHD: immediate and long-term effects from a randomized controlled trial. J Consult Clin Psychol. 2013 Feb;81(1):113–28. doi: 10.1037/a0029648. PMID: 22889336.22889336
109 Anand P, Sachdeva A. Effect of Poly Unsaturated Fatty Acids Administration on Children with Attention Deficit Hyperactivity Disorder: A Randomized Controlled Trial. J Clin Diagn Res. 2016 Sep;10(9):Oc01–oc5. doi: 10.7860/jcdr/2016/20423.8471. PMID: 27790483.27790483
110 Arcieri R, Germinario EA, Bonati M, . Cardiovascular measures in children and adolescents with attention-deficit/hyperactivity disorder who are new users of methylphenidate and atomoxetine. J Child Adolesc Psychopharmacol. 2012 Dec;22(6):423–31. PMID: 23362511.23362511
111 Arnold LE, Disilvestro RA, Bozzolo D, . Zinc for attention-deficit/hyperactivity disorder: placebo-controlled double-blind pilot trial alone and combined with amphetamine. J Child Adolesc Psychopharmacol. 2011 Feb;21(1):1–19. doi: 10.1089/cap.2010.0073. PMID: 21309695.21309695
112 Bai GN, Wang YF, Yang L, . Effectiveness of a focused, brief psychoeducation program for parents of ADHD children: Improvement of medication adherence and symptoms. Neuropsychiatr Dis Treat. 2015;11:2721–35.26604761
113 Banaschewski T, Johnson M, Lecendreux M, . Health-related quality of life and functional outcomes from a randomized-withdrawal study of long-term lisdexamfetamine dimesylate treatment in children and adolescents with attention-deficit/hyperactivity disorder. CNS Drugs. 2014 Dec;28(12):1191–203. doi: 10.1007/s40263-014-0193-z. PMID: 25139785.25139785
114 Barragan E, Breuer D, Dopfner M. Efficacy and Safety of Omega-3/6 Fatty Acids, Methylphenidate, and a Combined Treatment in Children With ADHD. J Atten Disord. 2014 Jan 24doi: 10.1177/1087054713518239. PMID: 24464327.24464327
115 Beck SJ, Hanson CA, Puffenberger SS, . A controlled trial of working memory training for children and adolescents with ADHD. J Clin Child Adolesc Psychol. 2010;39(6):825–36. doi: 10.1080/15374416.2010.517162. PMID: 21058129.21058129
116 Bink M, van Nieuwenhuizen C, Popma A, . Behavioral effects of neurofeedback in adolescents with ADHD: a randomized controlled trial. Eur Child Adolesc Psychiatry. 2015 Sep;24(9):1035–48. doi: 10.1007/s00787-014-0655-3. PMID: 25477074.25477074
117 Boyer BE, Geurts HM, Prins PJ, . Two novel CBTs for adolescents with ADHD: the value of planning skills. Eur Child Adolesc Psychiatry. 2015 Sep;24(9):1075–90. doi: 10.1007/s00787-014-0661-5. PMID: 25549767.25549767
118 Çetin FH, Taş Torun Y, Işik Taner Y. Atomoxetine versus OROS methylphenidate in attention deficit hyperactivity disorder: A six-month follow up study for efficacy and adverse effects. Turkiye Klinikleri Journal of Medical Sciences. 2015;35(2):88–96.
119 Chacko A, Bedard AC, Marks DJ, . A randomized clinical trial of Cogmed Working Memory Training in school-age children with ADHD: a replication in a diverse sample using a control condition. J Child Psychol Psychiatry. 2014 Mar;55(3):247–55. doi: 10.1111/jcpp.12146. PMID: 24117656.24117656
120 Clemow DB, Mason OW, Sarkis EH, . Atomoxetine monotherapy compared with combination therapy for the treatment of ADHD: a retrospective chart review study. Expert Rev Neurother. 2015 Oct 21;15(11):1353–66. doi: 10.1586/14737175.2015.1102060. PMID: 26488905.26488905
121 Cortese S, Panei P, Arcieri R, . Safety of Methylphenidate and Atomoxetine in Children with Attention-Deficit/Hyperactivity Disorder (ADHD): Data from the Italian National ADHD Registry. CNS Drugs. 2015 Oct;29(10):865–77. doi: 10.1007/s40263-015-0266-7. PMID: 26293742.26293742
122 Dovis S, Van der Oord S, Wiers RW, . Improving executive functioning in children with ADHD: training multiple executive functions within the context of a computer game. a randomized double-blind placebo controlled trial. PLoS One. 2015;10(4):e0121651. doi: 10.1371/journal.pone.0121651. PMID: 25844638.25844638
123 Didoni A, Sequi M, Panei P, . One-year prospective follow-up of pharmacological treatment in children with attention-deficit/hyperactivity disorder. Eur J Clin Pharmacol. 2011 Oct;67(10):1061–7. doi: 10.1007/s00228-011-1050-3. PMID: 21538145.21538145
124 Duric NS, Assmus J, Gundersen D, . Neurofeedback for the treatment of children and adolescents with ADHD: a randomized and controlled clinical trial using parental reports. BMC Psychiatry. 2012;12:107. doi: 10.1186/1471-244x-12-107. PMID: 22877086.22877086
125 Dutta B, Barua TK, Ray J, . A study of evaluation of safety and efficacy of memomet, a multi herbal formulation (memomet) in the treatment of behavioural disorder in children. International Journal of Research in Pharmaceutical Sciences. 2012;3(2):282–6.
126 Egeland J, Aarlien AK, Saunes BK. Few effects of far transfer of working memory training in ADHD: a randomized controlled trial. PLoS One. 2013;8(10):e75660. doi: 10.1371/journal.pone.0075660. PMID: 24124503.24124503
127 Ercan ES, Ardic UA, Kutlu A, . No beneficial effects of adding parent training to methylphenidate treatment for ADHD + ODD/CD children: a 1-year prospective follow-up study. J Atten Disord. 2014 Feb;18(2):145–57. doi: 10.1177/1087054711432884. PMID: 22522574.22522574
128 Evans SW, Langberg JM, Schultz BK, . Evaluation of a School-Based Treatment Program for Young Adolescents With ADHD. Journal of Consulting and Clinical Psychology. 2016;84(1):15–30.26501496
129 Ferrin M, Perez-Ayala V, El-Abd S, . A Randomized Controlled Trial Evaluating the Efficacy of a Psychoeducation Program for Families of Children and Adolescents With ADHD in the United Kingdom: Results After a 6-Month Follow-Up. J Atten Disord. 2016 Feb 2doi: 10.1177/1087054715626509. PMID: 26838557.26838557
130 Findling RL, Adeyi B, Chen G, . Clinical response and symptomatic remission in children treated with lisdexamfetamine dimesylate for attention-deficit/hyperactivity disorder. CNS Spectrums. 2010;15(9):559–68.
131 Gelade K, Janssen TW, Bink M, . Behavioral Effects of Neurofeedback Compared to Stimulants and Physical Activity in Attention-Deficit/Hyperactivity Disorder: A Randomized Controlled Trial. J Clin Psychiatry. 2016 Oct;77(10):e1270–e7. doi: 10.4088/JCP.15m10149. PMID: 27631143.27631143
132 Gevensleben H, Holl B, Albrecht B, . Is neurofeedback an efficacious treatment for ADHD? A randomised controlled clinical trial. J Child Psychol Psychiatry. 2009 Jul;50(7):780–9. doi: 10.1111/j.1469-7610.2008.02033.x. PMID: 19207632.19207632
133 Gustafsson PA, Birberg-Thornberg U, Duchen K, . EPA supplementation improves teacher-rated behaviour and oppositional symptoms in children with ADHD. Acta Paediatr. 2010 Oct;99(10):1540–9. doi: 10.1111/j.1651-2227.2010.01871.x. PMID: 20491709.20491709
134 Hahn-Markowitz J, Berger I, Manor I, . Efficacy of Cognitive-Functional (Cog-Fun) Occupational Therapy Intervention Among Children With ADHD: An RCT. J Atten Disord. 2016 Sep 16doi: 10.1177/1087054716666955. PMID: 27637735.27637735
135 Hammerness P, Petty C, Faraone SV, . Do Stimulants Reduce the Risk for Alcohol and Substance Use in Youth With ADHD? A Secondary Analysis of a Prospective, 24-Month Open-Label Study of Osmotic-Release Methylphenidate. J Atten Disord. 2012 Dec 20doi: 10.1177/1087054712468051. PMID: 23264367.23264367
136 Hariri M, Djazayery A, Djalali M, . Effect of n-3 supplementation on hyperactivity, oxidative stress and inflammatory mediators in children with attention-deficit-hyperactivity disorder. Malays J Nutr. 2012 Dec;18(3):329–35. PMID: 24568073.24568073
137 Hong SS, Cho SH. Treating attention deficit hyperactivity disorder with acupuncture: A randomized controlled trial. European Journal of Integrative Medicine. 2015.
138 Huang YH, Chung CY, Ou HY, . Treatment effects of combining social skill training and parent training in Taiwanese children with attention deficit hyperactivity disorder. Journal of the Formosan Medical Association. 2015;114(3):260–7.25777975
139 Johnson M, Ostlund S, Fransson G, . Omega-3/omega-6 fatty acids for attention deficit hyperactivity disorder: a randomized placebo-controlled trial in children and adolescents. J Atten Disord. 2009 Mar;12(5):394–401. doi: 10.1177/1087054708316261. PMID: 18448859.18448859
140 Katz M, Levine AA, Kol-Degani H, . A compound herbal preparation (CHP) in the treatment of children with ADHD: a randomized controlled trial. J Atten Disord. 2010 Nov;14(3):281–91. doi: 10.1177/1087054709356388. PMID: 20228219.20228219
141 Li JJ, Li ZW, Wang SZ, . Ningdong granule: a complementary and alternative therapy in the treatment of attention deficit/hyperactivity disorder. Psychopharmacology (Berl). 2011 Aug;216(4):501–9. doi: 10.1007/s00213-011-2238-z. PMID: 21416235.21416235
142 Manor I, Magen A, Keidar D, . The effect of phosphatidylserine containing Omega3 fatty-acids on attention-deficit hyperactivity disorder symptoms in children: a double-blind placebo-controlled trial, followed by an open-label extension. Eur Psychiatry. 2012 Jul;27(5):335–42. doi: 10.1016/j.eurpsy.2011.05.004. PMID: 21807480.21807480
143 Milte CM, Parletta N, Buckley JD, . Eicosapentaenoic and docosahexaenoic acids, cognition, and behavior in children with attention-deficit/hyperactivity disorder: a randomized controlled trial. Nutrition. 2012 Jun;28(6):670–7. doi: 10.1016/j.nut.2011.12.009. PMID: 22541055.22541055
144 Mohammadpour N, Jazayeri S, Tehrani-Doost M, . Effect of vitamin D supplementation as adjunctive therapy to methylphenidate on ADHD symptoms: A randomized, double blind, placebo-controlled trial. Nutr Neurosci. 2016 Dec 07:1–8. doi: 10.1080/1028415x.2016.1262097. PMID: 27924679.27924679
145 Mohammadi MR, Mostafavi SA, Keshavarz SA, . Melatonin effects in methylphenidate treated children with attention deficit hyperactivity disorder: a randomized double blind clinical trial. Iran J Psychiatry. 2012 Spring;7(2):87–92. PMID: 22952551.22952551
146 Molina BS, Hinshaw SP, Swanson JM, . The MTA at 8 years: prospective follow-up of children treated for combined-type ADHD in a multisite study. J Am Acad Child Adolesc Psychiatry. 2009 May;48(5):484–500. doi: 10.1097/CHI.0b013e31819c23d0. PMID: 19318991.19318991
147 Moreno-García I, Delgado-Pardoa G, de Reya CC-V, . Neurofeedback, pharmacological treatment and behavioral therapy in hyperactivity: Multilevel analysis of treatment effects on electroencephalography. International Journal of Clinical and Health Psychology. 2015;15(3):217–25. doi: 10.1016/j.ijchp.2015.04.003. PMID: 2015-48012-005.
148 Newcorn JH, Harpin V, Huss M, . Extended-release guanfacine hydrochloride in 6–17-year olds with ADHD: a randomised-withdrawal maintenance of efficacy study. J Child Psychol Psychiatry. 2016 Jun;57(6):717–28. doi: 10.1111/jcpp.12492. PMID: 26871297.26871297
149 Oberai P, Gopinadhan S, Varanasi R, . Homoeopathic management of attention deficit hyperactivity disorder: A randomised placebo-controlled pilot trial. Indian Journal of Research in Homeopathy. 2013;7(4):158–67.
150 Ostberg M, Rydell AM. An efficacy study of a combined parent and teacher management training programme for children with ADHD. Nord J Psychiatry. 2012 Apr;66(2):123–30. doi: 10.3109/08039488.2011.641587. PMID: 22150634.22150634
151 Panei P, Arcieri R, Bonati M, . Safety of psychotropic drug prescribed for attention-deficit/hyperactivity disorder in Italy. Adverse Drug Reaction Bulletin. 2010(260):999–1002.
152 Pfiffner LJ, Hinshaw SP, Owens E, . A two-site randomized clinical trial of integrated psychosocial treatment for ADHD-inattentive type. J Consult Clin Psychol. 2014 Dec;82(6):1115–27. doi: 10.1037/a0036887. PMID: 24865871.24865871
153 Power TJ, Mautone JA, Soffer SL, . A family-school intervention for children with ADHD: results of a randomized clinical trial. J Consult Clin Psychol. 2012 Aug;80(4):611–23. doi: 10.1037/a0028188. PMID: 22506793.22506793
154 Raz R, Carasso RL, Yehuda S. The influence of short-chain essential fatty acids on children with attention-deficit/hyperactivity disorder: a double-blind placebo-controlled study. J Child Adolesc Psychopharmacol. 2009 Apr;19(2):167–77. doi: 10.1089/cap.2008.070. PMID: 19364294.19364294
155 Salehi B, Imani R, Mohammadi MR, . Ginkgo biloba for attention-deficit/hyperactivity disorder in children and adolescents: a double blind, randomized controlled trial. Prog Neuropsychopharmacol Biol Psychiatry. 2010 Feb 1;34(1):76–80. doi: 10.1016/j.pnpbp.2009.09.026. PMID: 19815048.19815048
156 Sallee FR, Lyne A, Wigal T, . Long-term safety and efficacy of guanfacine extended release in children and adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009 Jun;19(3):215–26. doi: 10.1089/cap.2008.0080. PMID: 19519256.19519256
157 Sayer GR, McGough JJ, Levitt J, . Acute and Long-Term Cardiovascular Effects of Stimulant, Guanfacine, and Combination Therapy for Attention-Deficit/Hyperactivity Disorder. J Child Adolesc Psychopharmacol. 2016 Aug 2doi: 10.1089/cap.2015.0264. PMID: 27483130.27483130
158 Shakibaei F, Radmanesh M, Salari E, . Ginkgo biloba in the treatment of attention-deficit/hyperactivity disorder in children and adolescents. A randomized, placebo-controlled, trial. Complement Ther Clin Pract. 2015 May;21(2):61–7. doi: 10.1016/j.ctcp.2015.04.001. PMID: 25925875.25925875
159 Sibley MH, Graziano PA, Kuriyan AB, . Parent-teen behavior therapy + motivational interviewing for adolescents with ADHD. J Consult Clin Psychol. 2016 Aug;84(8):699–712. doi: 10.1037/ccp0000106. PMID: 27077693.27077693
160 Steiner NJ, Frenette EC, Rene KM, . Neurofeedback and cognitive attention training for children with attention-deficit hyperactivity disorder in schools. J Dev Behav Pediatr. 2014 Jan;35(1):18–27. doi: 10.1097/dbp.0000000000000009. PMID: 24399101.24399101
161 Storebo OJ, Gluud C, Winkel P, . Social-skills and parental training plus standard treatment versus standard treatment for children with ADHD--the randomised SOSTRA trial. PLoS One. 2012;7(6):e37280. doi: 10.1371/journal.pone.0037280. PMID: 22745657.22745657
162 Trzepacz PT, Spencer TJ, Zhang S, . Effect of atomoxetine on Tanner stage sexual development in children and adolescents with attention deficit/hyperactivity disorder: 18-month results from a double-blind, placebo-controlled trial. Curr Med Res Opin. 2011;27 Suppl 2:45–52. doi: 10.1185/03007995.2011.599372. PMID: 21973230.21973230
163 van der Donk M, Hiemstra-Beernink AC, Tjeenk-Kalff A, . Cognitive training for children with ADHD: a randomized controlled trial of cogmed working memory training and ‘paying attention in class’. Front Psychol. 2015;6:1081. doi: 10.3389/fpsyg.2015.01081. PMID: 26284005.26284005
164 Vidal R, Castells J, Richarte V, . Group therapy for adolescents with attention-deficit/hyperactivity disorder: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2015 Apr;54(4):275–82. doi: 10.1016/j.jaac.2014.12.016. PMID: 25791144.25791144
165 Widenhorn-Muller K, Schwanda S, Scholz E, . Effect of supplementation with long-chain omega-3 polyunsaturated fatty acids on behavior and cognition in children with attention deficit/hyperactivity disorder (ADHD): a randomized placebo-controlled intervention trial. Prostaglandins Leukot Essent Fatty Acids. 2014 Jul–Aug;91(1–2):49–60. doi: 10.1016/j.plefa.2014.04.004. PMID: 24958525.24958525
166 Zhang H, Du M, Zhuang S. Impact of long-term treatment of methylphenidate on height and weight of school age children with ADHD. Neuropediatrics. 2010 Aug;41(2):55–9. doi: 10.1055/s-0030-1261893. PMID: 20799150.20799150
167 Chacko A, Wymbs BT, Wymbs FA, . Enhancing traditional behavioral parent training for single mothers of children with ADHD. J Clin Child Adolesc Psychol. 2009 Mar;38(2):206–18. doi: 10.1080/15374410802698388. PMID: 19283599.19283599
168 Ferrin M, Moreno-Granados JM, Salcedo-Marin MD, . Evaluation of a psychoeducation programme for parents of children and adolescents with ADHD: immediate and long-term effects using a blind randomized controlled trial. Eur Child Adolesc Psychiatry. 2014 Aug;23(8):637–47. doi: 10.1007/s00787-013-0494-7. PMID: 24292412.24292412
169 Hiscock H, Sciberras E, Mensah F, . Impact of a behavioural sleep intervention on symptoms and sleep in children with attention deficit hyperactivity disorder, and parental mental health: randomised controlled trial. BMJ. 2015;350:h68. doi: 10.1136/bmj.h68. PMID: 25646809.25646809
170 Mautone JA, Marshall SA, Sharman J, . Development of a Family-School Intervention for Young Children With Attention Deficit Hyperactivity Disorder. School Psych Rev. 2012;41(4):447–66. PMID: 24353368.24353368
171 Myers K, Vander Stoep A, Zhou C, . Effectiveness of a telehealth service delivery model for treating attention-deficit/hyperactivity disorder: a community-based randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2015 Apr;54(4):263–74. doi: 10.1016/j.jaac.2015.01.009. PMID: 25791143.25791143
172 Pelsser LM, Frankena K, Toorman J, . Effects of a restricted elimination diet on the behaviour of children with attention-deficit hyperactivity disorder (INCA study): a randomised controlled trial. Lancet. 2011 Feb 5;377(9764):494–503. doi: 10.1016/s0140-6736(10)62227-1. PMID: 21296237.21296237
173 Tobaiqy M, Stewart D, Helms PJ, . Parental reporting of adverse drug reactions associated with attention-deficit hyperactivity disorder (ADHD) medications in children attending specialist paediatric clinics in the UK. Drug Saf. 2011 Mar 1;34(3):211–9. doi: 10.2165/11586050-000000000-00000. PMID: 21332245.21332245
174 van Dongen-Boomsma M, Vollebregt MA, Buitelaar JK, . Working memory training in young children with ADHD: a randomized placebo-controlled trial. J Child Psychol Psychiatry. 2014 Aug;55(8):886–96. doi: 10.1111/jcpp.12218. PMID: 24628438.24628438
175 Webster-Stratton CH, Reid MJ, Beauchaine T. Combining parent and child training for young children with ADHD. J Clin Child Adolesc Psychol. 2011;40(2):191–203. doi: 10.1080/15374416.2011.546044. PMID: 21391017.21391017
176 NCT01552915. ClinicalTrials.gov. https://clinicaltrials.gov/ct2/results?term=NCT01552915&Search=Search. Accessed February 23, 2017.
177 NCT00429273. ClinicalTrials.gov. https://clinicaltrials.gov/ct2/results?term=NCT00429273&Search=Search. Accessed February 23, 2017.
178 NCT00889915. ClinicalTrials.gov. https://clinicaltrials.gov/ct2/results?term=NCT00889915&Search=Search. Accessed February 23, 2017.
179 NCT01439126. ClinicalTrials.gov. https://clinicaltrials.gov/ct2/results?term=NCT01439126&Search=Search. Accessed February 23, 2017.
180 NCT01711021. ClinicalTrials.gov. https://clinicaltrials.gov/ct2/results?term=NCT01711021&Search=Search. Accessed February 23, 2017.
181 NCT00782080. ClinicalTrials.gov. https://clinicaltrials.gov/ct2/results?term=NCT00782080&Search=Search. Accessed February 23, 2017.
182 NCT02114632. ClinicalTrials.gov. https://clinicaltrials.gov/ct2/results?term=NCT02114632&Search=Search. Accessed February 23, 2017.
183 Bunte TL, Laschen S, Schoemaker K, . Clinical usefulness of observational assessment in the diagnosis of DBD and ADHD in preschoolers. J Clin Child Adolesc Psychol. 2013;42(6):749–61. doi: 10.1080/15374416.2013.773516. PMID: 23477379.23477379
184 Papadopoulos N, Sciberras E, Hiscock H, . The Efficacy of a Brief Behavioral Sleep Intervention in School-Aged Children With ADHD and Comorbid Autism Spectrum Disorder. J Atten Disord. 2015 Feb 2doi: 10.1177/1087054714568565. PMID: 25646022.25646022
185 Boyer BE, Geurts HM, Prins PJM, . One-year follow-up of two novel CBTs for adolescents with ADHD. European Child and Adolescent Psychiatry. 2015.
186 Steiner NJ, Frenette EC, Rene KM, . In-scho-ol neurofeedback training for ADHD: sustained improvements from a randomized control trial. Pediatrics. 2014 Mar;133(3):483–92. doi: 10.1542/peds.2013-2059. PMID: 24534402.24534402
187 Hovik KT, Saunes BK, Aarlien AK, . RCT of working memory training in ADHD: long-term near-transfer effects. PLoS One. 2013;8(12):e80561. doi: 10.1371/journal.pone.0080561. PMID: 24352414.24352414
188 Mostafavi SA, Mohammadi MR, Hosseinzadeh P, . Dietary intake, growth and development of children with ADHD in a randomized clinical trial of Ritalin and Melatonin co-administration: Through circadian cycle modification or appetite enhancement? Iran J Psychiatry. 2012 Summer;7(3):114–9. PMID: 23139692.23139692
189 Duric NS, Assmus J, Elgen IB. Self-reported efficacy of neurofeedback treatment in a clinical randomized controlled study of ADHD children and adolescents. Neuropsychiatr Dis Treat. 2014;10:1645–54. doi: 10.2147/ndt.s66466. PMID: 25214789.25214789
190 Milte CM, Parletta N, Buckley JD, . Increased Erythrocyte Eicosapentaenoic Acid and Docosahexaenoic Acid Are Associated With Improved Attention and Behavior in Children With ADHD in a Randomized Controlled Three-Way Crossover Trial. J Atten Disord. 2015 Nov;19(11):954–64. doi: 10.1177/1087054713510562. PMID: 24214970.24214970
191 Manor I, Magen A, Keidar D, . Safety of phosphatidylserine containing omega3 fatty acids in ADHD children: a double-blind placebo-controlled trial followed by an open-label extension. Eur Psychiatry. 2013 Aug;28(6):386–91. doi: 10.1016/j.eurpsy.2012.11.001. PMID: 23312676.23312676
192 Vitiello B, Elliott GR, Swanson JM, . Blood pressure and heart rate over 10 years in the multimodal treatment study of children with ADHD. Am J Psychiatry. 2012 Feb;169(2):167–77. doi: 10.1176/appi.ajp.2011.10111705. PMID: 21890793.21890793
193 Wangler S, Gevensleben H, Albrecht B, . Neurofeedback in children with ADHD: specific event-related potential findings of a randomized controlled trial. Clin Neurophysiol. 2011 May;122(5):942–50. doi: 10.1016/j.clinph.2010.06.036. PMID: 20843737.20843737
194 Gevensleben H, Holl B, Albrecht B, . Neurofeedback training in children with ADHD: 6-month follow-up of a randomised controlled trial. Eur Child Adolesc Psychiatry. 2010 Sep;19(9):715–24. doi: 10.1007/s00787-010-0109-5. PMID: 20499120.20499120
195 Johnson M, Mansson JE, Ostlund S, . Fatty acids in ADHD: plasma profiles in a placebo-controlled study of Omega 3/6 fatty acids in children and adolescents. Atten Defic Hyperact Disord. 2012 Dec;4(4):199–204. doi: 10.1007/s12402-012-0084-4. PMID: 22753087.22753087
196 March JS. The preschool ADHD treatment study (PATS) as the culmination of twenty years of clinical trials in pediatric psychopharmacology. Journal of the American Academy of Child & Adolescent Psychiatry. 2011;50(5):427–30. doi: 10.1016/j.jaac.2010.09.018. PMID: 2011-10428-002.21515189
197 Andriola MR. Efficacy and safety of methylphenidate and pemoline in children with attention deficit hyperactivity disorder. Curr Ther Res Clin E. 2000 Apr;61(4):208–15. doi: Doi 10.1016/S0011-393x(00)89035-9. PMID: WOS:000086999500004.
198 Holick CN, Turnbull BR, Jones ME, . Atomoxetine and cerebrovascular outcomes in adults. J Clin Psychopharmacol. 2009 Oct;29(5):453–60. doi: 10.1097/JCP.0b013e3181b2b828. PMID: 19745645.19745645
199 Barbaresi WJ, Katusic SK, Colligan RC, . Long-term stimulant medication treatment of attention-deficit/hyperactivity disorder: results from a population-based study. J Dev Behav Pediatr. 2006 Feb;27(1):1–10. PMID: 16511362.16511362
200 Pliszka SR, Matthews TL, Braslow KJ, . Comparative effects of methylphenidate and mixed salts amphetamine on height and weight in children with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2006 May;45(5):520–6. doi: 10.1097/01.chi.0000205702.48324.fd. PMID: 16670648.16670648
201 Poulton A, Cowell CT. Slowing of growth in height and weight on stimulants: a characteristic pattern. J Paediatr Child Health. 2003 Apr;39(3):180–5. PMID: 12654140.12654140
202 Sund AM, Zeiner P. Does extended medication with amphetamine or methylphenidate reduce growth in hyperactive children? Nord J Psychiatry. 2002;56(1):53–7. doi: 10.1080/08039480252803936. PMID: 11869467.11869467
203 Zachor DA, Roberts AW, Hodgens JB, . Effects of long-term psychostimulant medication on growth of children with ADHD. Res Dev Disabil. 2006 Mar–Apr;27(2):162–74. doi: 10.1016/j.ridd.2004.12.004. PMID: 15955659.15955659
204 Bloch MH, Qawasmi A. Omega-3 fatty acid supplementation for the treatment of children with attention-deficit/hyperactivity disorder symptomatology: systematic review and meta-analysis. J Am Acad Child Adolesc Psychiatry. 2011 Oct;50(10):991–1000. doi: 10.1016/j.jaac.2011.06.008. PMID: 21961774.21961774
205 Gillies D, Sinn J, Lad SS, . Polyunsaturated fatty acids (PUFA) for attention deficit hyperactivity disorder (ADHD) in children and adolescents. Cochrane Database Syst Rev. 2012;7:Cd007986. doi: 10.1002/14651858.CD007986.pub2. PMID: 22786509.22786509
206 Matos M, Bauermeister JJ, Bernal G. Parent-child interaction therapy for Puerto Rican preschool children with ADHD and behavior problems: a pilot efficacy study. Fam Process. 2009 Jun;48(2):232–52. PMID: 19579907.19579907
207 Sonuga-Barke EJ, Daley D, Thompson M, . Parent-based therapies for preschool attention-deficit/hyperactivity disorder: a randomized, controlled trial with a community sample. J Am Acad Child Adolesc Psychiatry. 2001 Apr;40(4):402–8. doi: 10.1097/00004583-200104000-00008. PMID: 11314565.11314565
208 Thompson MJ, Laver-Bradbury C, Ayres M, . A small-scale randomized controlled trial of the revised new forest parenting programme for preschoolers with attention deficit hyperactivity disorder. Eur Child Adolesc Psychiatry. 2009 Oct;18(10):605–16. doi: 10.1007/s00787-009-0020-0. PMID: 19404717.19404717
209 Belanger SA, Vanasse M, Spahis S, . Omega-3 fatty acid treatment of children with attention-deficit hyperactivity disorder: A randomized, double-blind, placebo-controlled study. Paediatr Child Health. 2009 Feb;14(2):89–98. PMID: 19436468.19436468
210 Cornell JE, Mulrow CD, Localio R, . Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. 2014 Feb 18;160(4):267–70. doi: 10.7326/M13-2886. PMID: 24727843.24727843
211 Williford AP, Shelton TL. Using mental health consultation to decrease disruptive behaviors in preschoolers: adapting an empirically-supported intervention. J Child Psychol Psychiatry. 2008 Feb;49(2):191–200. doi: 10.1111/j.1469-7610.2007.01839.x. PMID: 18211278.18211278
212 Shelton TL, Barkley RA, Crosswait C, . Multimethod psychoeducational intervention for preschool children with disruptive behavior: two-year post-treatment follow-up. J Abnorm Child Psychol. 2000 Jun;28(3):253–66. PMID: 10885683.10885683
213 Barkley RA, Shelton TL, Crosswait C, . Multi-method psycho-educational intervention for preschool children with disruptive behavior: preliminary results at post-treatment. J Child Psychol Psychiatry. 2000 Mar;41(3):319–32. PMID: 10784079.10784079
214 Kern L, DuPaul GJ, Volpe RJ, . Multisetting assessment-based intervention for young children at risk for attention deficit hyperactivity disorder: Initial effects on academic and behavioral functioning. School Psychology Review. 2007;36(2):237–55. PMID: WOS:000255736900004.
215 McGoey KE, DuPaul GJ, Eckert TL, . Outcomes of a multi-component intervention for preschool children at-risk for attention-deficit/hyperactivity disorder. Child & Family Behavior Therapy. 2005;27(1):33–56. doi: 10.1300/J019v27n01_03. PMID: WOS:000230131600003.
216 Pliszka S. Practice Parameter for the Assessment and Treatment of Children and Adolescents With Attention-Deficit/Hyperactivity Disorder. Journal of the American Academy of Child & Adolescent Psychiatry.46(7):894–921. doi: 10.1097/chi.0b013e318054e724.
217 Gloss D, Varma JK, Pringsheim T, . Practice advisory: The utility of EEG theta/beta power ratio in ADHD diagnosis: Report of the Guideline Development, Dissemination, and Implementation Subcommittee of the American Academy of Neurology. Neurology. 2016 Nov 29;87(22):2375–9. doi: 10.1212/wnl.0000000000003265. PMID: 2776086727760867