# Methods

For this comparative effectiveness review, we followed the methods from the Agency for Healthcare Research and Quality (AHRQ)’s Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter referred to as the Methods Guide) for the Evidence-based Practice Center (EPC) program.^20^ We sought feedback regarding the conduct of the work (such as development of search strategies and identifying outcomes of key importance) from the Task Order Officer and the Technical Expert Panel. Our methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.^21^ All methods and analyses were determined a priori.

## Topic Refinement and Review Protocol

During topic refinement, we engaged in a public process to develop a draft and final protocol for the review. We generated an analytic framework, preliminary Key Questions (KQs), and preliminary inclusion/exclusion criteria in the form of PICOTS (populations, interventions, comparators, outcomes, timing, settings). Initially a panel of 9 key informants representing medical professionals with expertise in areas of family medicine, child and adolescent psychiatry, psychology, and pediatrics; payers; Federal agencies; and patients/caregivers gave input on the KQs to be examined; these KQs were posted on AHRQ’s Effective Health Care (EHC) Web site for public comment from June 17, 2015, to July 8, 2015, and were revised to refine the scoping for KQ 1 and KQ 2, clarify the exclusion of pre–post studies, and update the grey literature to be searched. These revisions were made prior to seeing the results of any studies.

We then drafted a protocol for the systematic review and recruited a panel of technical experts to provide clinical content and methodological expertise throughout the development of the review. This panel included medical professional and Federal agency representation similar to that of the key informant group. The finalized protocol is posted on the EHC Web site (www.effectivehealthcare.ahrq.gov). The PROSPERO registration is CRD42016029134.

## Literature Search Strategy

### Search Strategy

To identify relevant published literature, we searched MEDLINE^®^ (via PubMed), Embase^®^, PsycINFO^®^, and the Cochrane Database of Systematic Reviews (CDSR), limiting the search to studies conducted in children 17 years of age and younger and published from January 1, 2009, to November 7, 2016. These databases were selected based on internal expert opinion that they would identify most of the relevant literature on this topic and following prior related systematic reviews. We believe that the evidence published from 2009 forward both represents the current standard of care for the population of interest in this review and allows this report to build on the previous systematic review published in 2011 (which included literature through May 31, 2010).^4^

We used a combination of medical subject headings and title and abstract keywords, focusing on terms to describe the relevant population and interventions of interest. Exact search strings used for each KQ are in Appendix A. Where possible, we used existing validated search filters. An experienced search librarian guided all searches. We supplemented the electronic searches with a manual search of citations from a set of key primary and review articles.^22–79^ The reference list for identified pivotal articles was hand-searched and cross-referenced against our database, and additional relevant manuscripts were retrieved. All citations were imported into an electronic bibliographical database (EndNote^®^ Version X7; Thomson Reuters, Philadelphia, PA).

To identify relevant gray literature, the EPC Scientific Resource Center made requests to drug and device manufacturers for scientific information packets solicited through the AHRQ EHC Web site. We also searched study registries for relevant articles from completed studies. Gray literature databases included ClinicalTrials.gov, the World Health Organization International Clinical Trials Registry Platform search portal, and the National Guidelines Clearinghouse.

As an additional step in identifying adverse effects of interest, we reviewed the known adverse effects of attention deficit hyperactivity disorder (ADHD) medications monitored by the Food and Drug Administration (FDA).^80^ As a result of that assessment, we added two additional outcomes to consideration for this review: chemical leukoderma and priapism.

### Inclusion and Exclusion Criteria

We specified our inclusion and exclusion criteria based on the PICOTS (Populations, Interventions, Comparators, Outcomes, Timing, Settings) identified in topic refinement. Table 1 specifies inclusion and exclusion criteria.

Table 1 Inclusion and exclusion criteria

PICOTS Element | Inclusion Criteria | Exclusion Criteria
Populations | KQ 1: Individuals birth through 17 years of age without the diagnosis of ADHD, divided by subquestion as follows:; - KQ 1a considers the initial diagnosis of individuals under 7 years of age.; - KQ 1b considers the initial diagnosis of individuals through 17 years of age using EEG, imaging, or executive function approaches.; - KQs 1c and 1d considers both populations.; KQ 2: Individuals birth through 17 years of age with a diagnosis of ADHD KQ 3: Individuals birth through 17 years of age who have previously begun treatment for ADHD Subgroups of interest for KQs 1–3:; - The general population of children and adolescents: ages less than 4, 4–6, 7–12, and 13–17 years; - When data are available, findings are separately evaluated by sex or specific risk factors (prenatal tobacco, alcohol, or substance abuse; prematurity or low birth weight; and family history); ADHD presentation; comorbidity; race/ethnicity; socioeconomic status; insurance status; geographic location | Individuals 18 years of age or older. Note that studies with individuals greater than 18 years of age are included as long as findings are reported separately for individuals 18 years and under, or if the mean patient age plus the standard deviation is not greater than 21 years of age. Also note that for long-term studies, the age of the individuals may be greater than 18, but these studies are only considered for inclusion if the age at enrollment in the study was 18 years or younger. Administrative claims data used for diagnosis of ADHD
Interventions | KQ 1: Any standard ADHD diagnostic strategy, including clinician interview or standardized instrument (e.g., Vanderbilt scales, the Conner scales, and the SNAP-IV rating score) for individuals under 7 years of age. The use of EEG-based systems, imaging, or assessment of executive function were evaluated in the diagnosis of ADHD in individuals through 17 years of age. KQ 2: Any pharmacologic or nonpharmacologic treatment of ADHD, alone or in combination:; - Pharmacologic treatments considered are brand name and generic formulations of the following medications^a^:; ○ Psychostimulants; ■ Methylphenidate (MPH); ■ Dexmethylphenidate (D-TMP); ■ Dextroamphetamine (DEX); ■ Lisdexamfetamine (LDX); ■ Mixed amphetamine salts (MAS); ■ Amphetamine; ○ Tricyclic antidepressants; ■ *Desipramine; ■ *Nortriptyline; ○ Selective norepinephrine reuptake inhibitors; ■ Atomoxetine (ATX); ○ Alpha-2 agonists; ■ Clonidine; ■ Guanfacine extended release (GXR); ■ *Guanfacine immediate release (GIR); ○ Dopamine reuptake inhibitors; ■ *Modafinil; ■ *Armodafinil; ○ Norepinephrine-dopamine reuptake inhibitors; ■ *Bupropion; ○ Serotonin-norepinephrine reuptake inhibitors; ■ *Duloxetine; ○ Serotonin-norepinephrine-dopamine reuptake inhibitors; ■ *Venlafaxine; ○ Monoamine oxidase type B inhibitors; ■ *Selegiline; ○ N-methyl-D-aspartate receptor antagonists; ■ *Amantadine; ■ *Memantine; - Nonpharmacologic therapies considered include psychosocial interventions, behavioral interventions, cognitive behavioral therapy, play therapy, mindfulness-based therapies, school interventions, cognitive training therapies, biofeedback or neurofeedback, parent behavior training, dietary supplements (e.g., omega-3 fatty acids, vitamins, herbal supplements, probiotics), homeopathy, acupuncture, elimination diets, vision training, exercise, and chiropractic treatment.; KQ 3: Follow-up visits in primary care with various methods and within times (monthly to annually) for repeat monitoring, independent of treatment. | KQ 1: Validation studies or diagnosis conducted using a nonvalidated instrument KQ 2: Studies comparing pharmacologic agents approved by the FDA for the treatment of ADHD that have enrollment of fewer than 100 patients with ADHD, or less than 6 months of follow-up
Comparators | KQ 1: Confirmation of diagnosis by a specialist (gold standard), including psychologist or psychiatrist or other care provider using a well-validated and reliable process of confirming the diagnosis of ADHD according to the DSM-4 or DSM-5. KQ 2: Specific treatments compared with other treatments as described above or to no treatment. KQ 3: Follow-up compared with differing durations of follow-up or differing settings of follow-up. | KQ 1: Comparison to diagnosis with a nonvalidated instrument
Outcomes | KQ 1:; - Accuracy of diagnostic strategy, as measured by:; ○ Diagnostic concordance of primary care provider with specialist; ○ Inter-rater reliability; ○ Internal consistency; ○ Test-retest; ○ Sensitivity; ○ Specificity; ○ Positive predictive value; ○ Negative predictive value; ○ False positives; ○ False negatives; ○ Risk of missed condition that can appear as ADHD (i.e., misdiagnosis); - Labeling is any measure of stigma following diagnosis comparing those with and without ADHD.; KQ 2:; - Intermediate outcomes:; ○ Changes on standardized symptom scores or progress toward patient-identified goals. Standardized symptom scores include narrow-band focused instruments (Vanderbilt rating scales, ADHD Rating Scale) and broad-band scales (Child Behavior Checklist and Teacher Report Form, Behavior Assessment System for Children, Conners’ Rating Scales-Revised, Conners’ 3 Parent, Conners’ 3 Teacher); ○ Acceptability of treatment; ○ Functional impairment (assessed using the Clinical Global Impressions [CGI] scale or the Impairment Rating Scale [IRS]); - Final outcomes include:; ○ Academic performance; ■ Academic Performance Rating Scale; ■ Academic Competency Evaluation Scale (ACES); ■ (Actual) School grades; ■ Grade Retention/Not being promoted; ■ Vanderbilt Teacher Form Academic Performance Subscale; ■ Standardized achievement tests (WIAT, WJ, WRAT); ○ Workforce participation; ○ Quality of peer relationships; ○ Divorce/relationship status; ○ Motor vehicle collisions or other accidents; ○ Motor vehicle violations; ○ Risk-taking behaviors; ○ Incarceration or other interactions with the legal system (juvenile detention, probation, court-mandated interventions, need for residential placement); ○ Obesity; ○ Tobacco use; ○ Substance abuse; ○ Mood disorders; ○ Depression or anxiety; ○ Self-injurious nonsuicidal behavior; ○ Suicide (attempted or completed); ○ Suicidal ideation; ○ Mortality; - Adverse effects of treatment, including:; ○ Changes in appetite; ○ Growth suppression; ○ Weight decrease; ○ Sleep disturbance; ○ Gastrointestinal symptoms; ○ Elevated blood pressure; ○ Increased heart rate; ○ Risk of sudden cardiac death; ○ Cardiac arrhythmias; ○ Conduction abnormalities; ○ Tics or other movement disorders; ○ Behavior changes; ○ Hallucination; ○ Aggression; ○ Suicide (attempted or completed); ○ Suicidal ideation; ○ Overtreatment; ○ Diversion of pharmacotherapy; ○ Parental stress; ○ Personality change; ○ Time demands/opportunity cost; ○ Loss of spontaneity; ○ Chemical leukoderma; ○ Priapism; KQ 3:; - Changes in treatment or dose; - Adverse effects of treatment as described under KQ 2; - Changes in intermediate outcomes (e.g., standardized symptom scores, progress toward patient-identified goals, functional impairment) as described under KQ 2
Timing | KQ 1:; - For assessment of diagnostic accuracy: diagnostic follow-up must be within 4 months of the initial evaluation and must be completed before treatment is initiated; - For labeling: any time after the ADHD diagnosis; KQs 2 and 3: Any
Settings | KQ 1: Primary or specialty care settings KQs 2 and 3: Any | None
Study design | - Original data; - Randomized trials, prospective and retrospective observational studies with comparator; for diagnostic accuracy, cross-sectional studies are acceptable if they include patients with diagnostic uncertainty and direct comparison of diagnosis in primary care to diagnosis by a specialist; - Randomized controlled trials with sample size:; ○ ≥20 subjects for KQs 1 and 3; ○ ≥50 subjects for KQ 2 (or 100 subjects for studies comparing two or more pharmacologic treatments approved by the FDA for the treatment of ADHD); - Observational studies with sample size:; ○ ≥20 subjects for KQs 1 and 3; ○ ≥50 subjects for KQ 2 (or 100 subjects for studies comparing two or more pharmacologic treatments approved by the FDA for the treatment of ADHD) | Editorials, nonsystematic reviews, letters, case series, case reports, abstract-only, pre-post studies Because studies with fewer than 20 subjects are often pilot studies or studies of lower quality, we excluded them from our review. Given the large evidence base for comparative pharmacologic treatment studies in KQ2 we increased this sample size limit to 50 subjects for KQ2 and to 100 subjects for studies comparing two or more pharmacologic treatments approved by the FDA for the treatment of ADHD. These sample size limits were seen as representing population study sizes that would be needed to substantially impact the assessment of the existing evidence base.
Publications | - English-language publications only; - Published on or after January 1, 2009; - Relevant systematic reviews, meta-analyses, or methods articles (used for background only)^b^ | Non-English language articles^c^

a Pharmacologic treatments listed are FDA-approved for an indication of ADHD with the exception of those marked with an asterisk, which are available within the United States and are FDA-approved but not specifically approved for ADHD.

b Systematic reviews and meta-analyses were excluded from direct abstraction; those representing key sources were hand-searched as potential sources of additional citations to consider in the review.

c Non-English language articles were excluded due to: (1) the high volume of literature available in English language publications, (2) the focus of our review on applicability to populations in the United States, and (3) the scope of our KQs.

Abbreviations: ADHD=attention deficit hyperactivity disorder; ATX=atomoxetine; DEX=dextroamphetamine; CGI=Clinical Global Impressions scale; DSM=Diagnostic and Statistical Manual of Mental Disorders; D-TMP=dexmethylphenidate; EEG=electroencephalograph; GIR=Guanfacine immediate release; GXR=guanfacine extended release; IRS=Impairment Rating Scale; KQ=Key Question; LDX=lisdexamfetamine; MAS=mixed amphetamine salts; MPH=methylphenidate; PICOTS=Populations, Interventions, Comparators, Outcomes, Timing, Settings; RCT=randomized controlled trial; WIAT= Wechsler Individual Achievement Test; WJ=Woodcock-Johnson; WRAT=Wide Range Achievement Test

### Study Selection

For citations retrieved from MEDLINE, Embase, PsycINFO, and CDSR, two reviewers used the prespecified inclusion/exclusion criteria to review titles and abstracts for potential relevance to the research questions. Articles included by either reviewer underwent full-text screening. At the full-text screening stage, two independent reviewers were required to agree on a final inclusion/exclusion decision. Disagreements were resolved by a third expert member of the team. Articles meeting eligibility criteria were included for data abstraction. At random intervals during screening, quality checks by senior team members were made to ensure that screening and abstraction were consistent with inclusion/exclusion criteria and abstraction guidelines. All results were tracked using the DistillerSR data synthesis software program (Evidence Partners Inc., Manotick, ON, Canada).

Appendix C provides a list of all articles included for data abstraction. Appendix D provides a list of articles excluded at the full-text screening stage, with reasons for exclusion.

### Data Extraction

The research team created abstraction forms that were programmed into DistillerSR software to collect the data required to evaluate the specified eligibility criteria for inclusion in this review, as well as demographic and other data needed for determining outcomes (intermediate, final, and adverse events outcomes). Particular attention was given to describing the details of the treatment (e.g., pharmacotherapy dosing, methods of behavioral interventions), patient characteristics (e.g., ADHD presentation, comorbidities, age), and study design (e.g., randomized controlled trial [RCT] versus observational) that may be related to outcomes. Comparators were described carefully because treatment standards may have changed during the period covered by the review. The safety outcomes were framed to help identify adverse events, including those from drug therapies and those resulting from misdiagnosis and labeling.

All data abstraction form templates were pilot-tested with a sample of included articles to ensure that all relevant data elements (Appendix B) were captured and that there was consistency and reproducibility between abstractors. Forms were revised as necessary before full abstraction of all included articles. Final abstracted data will be uploaded to AHRQ’s Systematic Review Data Repository.^81^

Based on clinical and methodological expertise, a pair of researchers abstracted data from each of the eligible articles, with one researcher abstracting the data and the second over-reading the article and the accompanying abstraction to check for accuracy and completeness. Disagreements were resolved by consensus or by obtaining a third reviewer’s opinion if consensus was not reached. To avoid duplication of patient cohorts, we linked related studies.

## Quality Assessment of Individual Studies

We assessed the methodological quality, or risk of bias, for each individual study based on the Cochrane Risk of Bias^82^ tool for randomized studies and the Newcastle-Ottawa Scale^83^ for observational studies. We supplemented these tools with additional assessment questions, such as use of appropriate analysis, based on recommendations in the AHRQ’s Methods Guide.^20^ We rated each study as being of good, fair, or poor quality based on its adherence to well-accepted standard methodologies. Table 2 defines these quality ratings, which are presented in the results tables in the Results section as well as the strength of evidence (SOE) tables in the Discussion section of the report.

Table 2 Definition of quality assessment ratings

Rating | Definition
Good (low risk of bias) | These studies had the least bias, and the results were considered valid. These studies adhered to the commonly held concepts of high quality, including the following: a clear description of the population, setting, approaches, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytical methods and reporting; no reporting errors; a low dropout rate; and clear reporting of dropouts.
Fair | These studies were susceptible to some bias, but not enough to invalidate the results. They did not meet all the criteria required for a rating of good quality because they had some deficiencies, but no flaw was likely to cause major bias. The study may have been missing information, making it difficult to assess limitations and potential problems.
Poor (high risk of bias) | These studies had significant flaws that might have invalidated the results. They had serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.

The grading was outcome-specific such that a given study that analyzed its primary outcome well but did an incomplete analysis of a secondary outcome was assigned a different quality grade for each of the two outcomes. Studies of different designs were graded within the context of their respective design. Thus, RCTs were graded as good, fair, or poor, and observational studies were separately graded as good, fair, or poor.

## Data Synthesis

We began by summarizing key features of the included studies for each KQ. To the degree that data were available, we abstracted information on study design; patient characteristics; clinical settings; interventions; and intermediate, final, and adverse event outcomes. We ordered our findings by treatment or diagnostic comparison and then within these comparisons by outcome with long-term final outcomes emphasized. Existing systematic reviews were used to identify potentially eligible studies. Individual studies from previous systematic reviews were not directly synthesized with the included studies if they did not meet our inclusion criteria. We did however compare the findings from our included studies with findings from key systematic reviews.

We reviewed and highlighted studies using a hierarchy-of-evidence approach. The best evidence available was the focus of our synthesis for each KQ. If high quality evidence was not available, we described any lower quality evidence we were able to identify, but we underscored the issues that made it lower quality and the uncertainties in our findings. We assessed and stated whether the inclusion of lower quality studies would change any of our conclusions and performed sensitivity analyses excluding this evidence where appropriate.

We then determined the feasibility of completing quantitative syntheses (i.e., meta-analyses). Feasibility was dependent on the volume of relevant literature (we required 3 appropriate studies to consider meta-analysis), conceptual homogeneity of the studies, and completeness of the reporting of results. When a meta-analysis was appropriate, we used random-effects models to synthesize the available evidence quantitatively. We tested for heterogeneity using graphical displays and test statistics (Q and I^2^ statistics), while recognizing that the ability of statistical methods to detect heterogeneity may be limited. We presented summary estimates, standard errors, and confidence intervals. We anticipated that intervention effects may be heterogeneous. We hypothesized that the methodological quality of individual studies, study type, the characteristics of the comparator, and patients’ underlying clinical presentation were associated with the intervention effects. When there were sufficient studies, we performed subgroup analyses and/or meta-regression analyses to examine these hypotheses. We performed quantitative and qualitative syntheses separately by study type and discussed their consistency qualitatively. When only qualitative synthesis was possible, this was done through a narrative description of the findings based on reasoned judgement rather than based on statistical inference.

## Strength of the Body of Evidence

We assessed the SOE using the approach described in AHRQ’s Methods Guide.^20, 84^ We graded the SOE for each outcome assessed; thus, the SOE for two separate outcomes in a given study may be graded differently. These grades are presented in the SOE tables in the Discussion section of the report. The approach requires assessment of five domains: study limitations (previously named risk of bias), consistency, directness, precision, and reporting bias, which includes publication bias, outcome reporting, and analysis reporting bias (Table 3).^84^

Table 3 Required domains: Definitions and scores

Domain | Definition and Elements | Score and Application
Study Limitations | Study limitations is the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through two main elements:; - Study design: Whether RCTs or other designs such as nonexperimental or observational studies.; - Study conduct. Aggregation of ratings of risk of bias of the individual studies under consideration. | Score as one of three levels, separately by type of study design:; - Low level of study limitations; - Medium level of study limitations; - High level of study limitations
Directness | Directness relates to (a) whether evidence links interventions directly to a health outcome of specific importance for the review, and (b) for comparative studies, whether the comparisons are based on head-to-head studies. The EPC should specify the comparison and outcome for which the SOE grade applies. Evidence may be indirect in several situations such as:; - The outcome being graded is considered intermediate (such as laboratory tests) in a review that is focused on clinical health outcomes (such as morbidity, mortality).; - Data do not come from head-to-head comparisons but rather from two or more bodies of evidence to compare interventions A and B—e.g., studies of A vs. placebo and B vs. placebo, or studies of A vs. C and B vs. C but not direct comparisons of A vs. B.; - Data are available only for proxy respondents (e.g., obtained from family members or nurses) instead of directly from patients for situations in which patients are capable of self-reporting and self-report is more reliable.; Indirectness always implies that more than one body of evidence is required to link interventions to the most important health outcome. | Score as one of two levels:; - Direct; - Indirect; If the domain score is indirect, EPCs should specify what type of indirectness accounts for the rating.
Consistency | Consistency is the degree to which included studies find either the same direction or similar magnitude of effect. EPCs can assess this through two main elements:; - Direction of effect: Effect sizes have the same sign (that is, are on the same side of no effect or a minimally important difference [MID]); - Magnitude of effect: The range of effect sizes is similar. EPCs may consider the overlap of CIs when making this evaluation.; The importance of direction vs. magnitude of effect will depend on the Key Question and EPC judgments. | Score as one of three levels:; - Consistent; - Inconsistent; - Unknown (e.g., single study); Single-study evidence bases (including mega-trials) cannot be judged with respect to consistency. In that instance, use “Consistency unknown (single study).”
Precision | Precision is the degree of certainty surrounding an effect estimate with respect to a given outcome, based on the sufficiency of sample size and number of events.; - A body of evidence will generally be imprecise if the optimal information size (OIS) is not met. OIS refers to the minimum number of patients (and events when assessing dichotomous outcomes) needed for an evidence base to be considered adequately powered.; - If EPCs performed a meta-analysis, then EPCs may also consider whether the CI crossed a threshold for an MID.; - If a meta-analysis is infeasible or inappropriate, EPCs may consider the narrowness of the range of CIs or the significance level of p values in the individual studies in the evidence base. | Score as one of two levels:; - Precise; - Imprecise; A precise estimate is one that would allow users to reach a clinically useful conclusion (e.g., treatment A is more effective than treatment B).
Reporting Bias | Reporting bias results from selectively publishing or reporting research findings based on the favorability of direction or magnitude of effect. It includes:; - Study publication bias; i.e., nonreporting of the full study.; - Selective outcome reporting bias; i.e., nonreporting (or incomplete reporting) of planned outcomes or reporting of unplanned outcomes.; - Selective analysis reporting bias, i.e., reporting of one or more favorable analyses for a given outcome while not reporting other, less favorable analyses.; Assessment of reporting bias for individual studies depends on many factors–e.g. availability of study protocols, unpublished study documents, and patient-level data. Detecting such bias is likely with access to all relevant documentation and data pertaining to a journal publication, but such access is rarely available. Because methods to detect reporting bias in observational studies are less certain, this guidance does not require EPCs to assess it for such studies. | Score as one of two levels:; - Suspected; - Undetected; Reporting bias is suspected when:; - Testing for funnel plot asymmetry demonstrates a substantial likelihood of bias,; And/or; - A qualitative assessment suggests the likelihood of missing studies, analyses, or outcomes data that may alter the conclusions from the reported evidence.; Undetected reporting bias includes all alternative scenarios.

CI=confidence internal; EPC=Evidence-based Practice Center; MID=minimally important difference; OIS=optimal information size; RCT=randomized controlled trial

Additional domains were used when appropriate (most relevant to observational studies) and included coherence, dose-response association, impact of plausible residual confounders, and strength of association (magnitude of effect). These domains were considered qualitatively, and a summary rating of high, moderate, or low SOE was assigned for each outcome after discussion by two reviewers. In some cases, high, moderate, or low ratings were impossible or imprudent to make, for example, when no evidence is available or when evidence on the outcome was too weak, sparse, or inconsistent to permit any conclusion to be drawn. In these situations, a grade of “insufficient” was assigned. Table 4 defines the four-level grading scale.

Table 4 Definition of strength of evidence grades

Rating | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

## Applicability

We assessed applicability across our KQs using the method described in AHRQ’s Methods Guide.^20, 85^ In brief, this method uses the PICOTS format as a way to organize information relevant to applicability. The most important issue with respect to applicability is whether the outcomes are different across studies that recruit different populations (e.g., age groups, ADHD presentations, exclusions for comorbidities) or use different methods to implement the interventions of interest; that is, important characteristics are those that affect baseline (control group) rates of events, intervention group rates of events, or both. We used a checklist to guide assessment of the applicability to clinical practice, paying special attention to study eligibility criteria, demographic features of the enrolled population in comparison with the target population, characteristics of the intervention used in comparison with care models currently in use, the possibility of diagnostic tool or treatment intervention learning curves, and clinical relevance and timing of the outcome measures (Appendix B). We summarized issues of applicability qualitatively.

## Peer Review and Public Commentary

Experts in the fields of pediatrics and child development, child psychiatry and psychology, pharmacology, and public health were invited to provide external peer review of the draft report. AHRQ, an associate editor, and members of the Technical Expert Panel were also given the opportunity to provide comments. In addition, the draft report was posted on the AHRQ EHC Web site for public comment from October 17, 2016, to November 14, 2016. We have addressed all reviewer comments, revising the text as appropriate, and have documented our responses in a disposition of comments report that will be made available 3 months after the Agency posts the final systematic review on the EHC Web site. A list of peer reviewers submitting comments on the draft report is provided in the front matter of this report.