# Introduction

## Background

Attention deficit hyperactivity disorder (ADHD) is a common neurobehavioral disorder, with about 11 percent of children ages 4 through 17 having been diagnosed.^1^ In the United States, there are significant geographical variations in the rate of diagnosis and treatment, and the prevalence has increased over time.^1, 2^ The most recent Diagnostic and Statistical Manual of Mental Disorders (DSM-5)^3^ has revised the diagnostic criteria for ADHD. To be diagnosed with ADHD, a child or younger adolescent needs to meet six out of nine possible inattentive symptoms (such as failing to give close attention to details or being easily distracted) and/or six out of nine possible hyperactivity/impulsivity symptoms (such as being “on the go” or difficulty waiting their turn). Also, symptoms need to be present for at least 6 months, occur in at least two different settings, be present before 12 years of age, and not be better explained by another disorder. For older adolescents and adults, the number of required symptoms per category is reduced to five out of nine. ADHD has three presentations: (1) predominantly inattentive, (2) predominantly hyperactive/impulsive, and (3) combined, based on how many symptoms in each diagnostic category an individual meets. ADHD that does not clearly fall into these categories can be referred to as ADHD-Not Otherwise Specified.

Psychostimulants can be effective in reducing distractibility, improving sustained attention, reducing impulsive behaviors, and improving activity level.^4^ Nonpharmacologic therapies (e.g., behavioral therapy, psychotherapy, psychosocial interventions, and complementary and alternative medicine interventions), either alone or in combination with medication management, could potentially address core symptoms of ADHD or the long-term impairments that are associated with the disorder. Understanding the role of nonpharmacologic therapies can be challenging because they encompass a broad range of approaches to care, ranging from highly structured behavioral interventions to complementary medicines.

Despite growing research on treatment for ADHD and awareness of the condition’s course of illness, important questions remain about ADHD diagnosis and management. Ensuring appropriate diagnosis and avoidance of misdiagnosis is a key concern for clinical practice. For treatment, Key Questions include how to best tailor therapy to individuals based on their characteristics (e.g., age, sex, ADHD symptoms, comorbid conditions, prior and current therapy) and how to efficiently and effectively monitor individuals with ADHD over time.

### Population

This systematic review focuses on children through 17 years of age, categorized to reflect broad developmental stages (less than 4 years, 4 through 6 years, 7 through 12 years, and 13 through 17 years). We explored the impact of ADHD and its treatment and monitoring strategies in several subgroups of interest. These include sex because the clinical presentation can vary as can the response to therapy.^5^

Many risk factors have been associated with ADHD, including prenatal factors (e.g., tobacco use, alcohol use, substance abuse), perinatal factors (e.g., low birth weight, prematurity), and early postnatal factors (e.g., lead exposure, social environment).^6^ Also, family history of ADHD and specific genetic conditions (e.g., Fragile X syndrome) can be associated with ADHD. We evaluated these subpopulations by stratifying outcomes based on common these risk factors when available.

### Diagnosis

ADHD diagnosis is based on clinician assessment to determine whether the criteria described in the DSM are met. For this review, studies based on the DSM-5 or DSM-IV criteria were included. Rating scales, which can be completed by parents, teachers, and/or patients, are used to evaluate the presence of each of the 18 symptoms as well as the degree of impairment that results from symptoms. Rating scale data are integrated with a clinical interview to determine the onset, course, duration, and impairment associated with symptoms. In addition, screening and clinical evaluation of potential comorbid psychiatric conditions is a key part of the diagnostic process. Important questions remain about the accuracy of this approach in primary care settings. A particular challenge in primary care has been the lack of adequate time and expertise to distinguish ADHD from other conditions that may appear similar (e.g., anxiety, conduct disorders, speech or language delay, other developmental disorders) and to determine whether another condition may better explain ADHD symptoms or is present as a comorbid diagnosis.^7^

Although most previous research has relied on interviews and rating scales for diagnosis, the U.S. Food and Drug Administration (FDA) has recently approved a new device “to aid in the diagnosis of ADHD.”^8^ The Neuropsychiatric Electroencephalograph [EEG]-Based Assessment Aid (NEBA; NEBA Health, Augusta, GA) was approved to provide clinical support for an ADHD diagnosis in patients ages 6–17 years but is not intended to replace the clinical evaluation.^8^ There is significant interest in the use of tests to either supplement or replace the standard methods of diagnosis used in the primary care setting.

#### Adverse Effects of Diagnosis

Being diagnosed with ADHD can lead to “labeling harms,” which can lead to stigma, reduced self-esteem, or reduced future educational attainment or career opportunities.^9–11^ Misdiagnosis can lead to overdiagnosis or underdiagnosis and can also miss conditions that can be similar in appearance to ADHD (e.g., anxiety, conduct disorders, speech or language delay, other medical disorders/diseases, or other developmental disorders) that may warrant a different course of treatment.

### Treatment Strategies

Treatment strategies for ADHD can be divided into pharmacologic and nonpharmacologic therapies. The main categories of pharmacologic therapies include stimulants, selective norepinephrine reuptake inhibitors, alpha-2 agonists, and antidepressants. Nonpharmacologic therapies include psychosocial interventions, behavioral interventions, school interventions, cognitive training therapies, learning training, biofeedback or neurofeedback, parent behavior training (i.e., training parents to reduce unwanted behaviors, foster desired behaviors and interactions, and improve family relationships), dietary supplements (e.g., omega-3 fatty acids, vitamins, herbal supplements, probiotics), elimination diets, vision training, and chiropractic treatment. For the first line of therapy, the American Academy of Pediatrics (AAP) recommends behavior therapy for children 4–5 years of age and preferably both behavior therapy and FDA-approved medications for children 6–18 years of age.^12^

#### Adverse Effects of Treatment

Adverse effects associated with pharmacologic treatment can include changes in appetite, growth suppression,^13^ weight decrease, sleep disturbance, gastrointestinal symptoms, elevated blood pressure, increased heart rate, risk of sudden cardiac death, cardiac arrhythmias, conduction abnormalities, tics or other movement disorders, behavior changes, hallucination, aggression, suicide (attempted or completed), and suicidal ideation. Importantly, suicide and suicidal ideation can be both an adverse effect of treatment and an ADHD-related health outcome. Treatment can also lead to personality changes or loss of spontaneity as perceived by the treated individual, family members, or other close acquaintances.

Individuals who are initially misdiagnosed may be overtreated, and those who have inadequate monitoring may be overtreated or undertreated. Overtreatment leads to risk of treatment with no or little potential benefit. Because many of the pharmacologic treatments are controlled substances, overtreatment could also lead to abuse of a drug to which the treated individual might not otherwise have access.^14^ Although reduction of ADHD symptoms can improve family functioning, the need to provide treatments can potentially also lead to parental stress, and depending on the specific treatment, there may be significant time demands, opportunity, or financial costs.

### Monitoring Strategies With Intermediate Outcomes

After a child is diagnosed with ADHD and an initial treatment strategy is determined, a monitoring strategy is applied to ensure that outcomes are evaluated over time and modification to treatments are made when needed. Stimulant prescription refills are often required monthly, which can also support the need for frequent re-evaluations. Several instruments are available to monitor treatment response and adverse effects over time, including the Vanderbilt scales, the Conners scales, and the Swanson, Nolan, and Pelham Revision (SNAP-IV) rating scales.^15–17^ Monitoring also includes assessment of any adverse effects of treatment. There are variations in the frequency of monitoring, often based on the age of the child, the specific treatment, duration of treatment, previous symptoms and comorbid conditions, and family and health care provider preferences. Rating scale results are intermediate monitoring outcomes associated with the outcomes described below.

### Long-Term Outcomes

Outcomes associated with ADHD in childhood are based on measures of performance and/or functional impairment. In childhood and adolescence, individuals with ADHD are at risk for lower academic performance (e.g., grades, scores on standardized tests), lower rates of graduation from high school, higher rates of grade retention, and higher rates of school suspension. In adulthood, outcomes may include limited workforce participation and/or difficulty maintaining a steady job. Throughout the lifespan, social outcomes associated with ADHD may include problematic peer and family relationships. Individuals with ADHD are also at risk for negative outcomes associated with risk-taking behaviors such as motor vehicle collisions or other accidents, substance use (e.g., higher rates of smoking, more difficulty quitting smoking), and unprotected sexual activity. Mental health outcomes that are associated with ADHD include higher rates of mood disorders, depression or anxiety, higher likelihood of having self-injurious nonsuicidal behavior, suicide (attempted or completed), suicidal ideation, and risk of mortality. Because these long-term outcomes can be associated with the known course of illness for ADHD, with commonly occurring comorbid conditions or in some cases with ADHD treatment, it can be difficult to fully assess and predict long-term outcomes for individuals with ADHD.

### Key Findings From 2011 Report

This review updates previous Agency for Healthcare Research and Quality (AHRQ) reports focused on ADHD treatment. This most recent report from 2011 focused on (1) pharmacologic treatments for children under 6 years of age with ADHD and a disruptive behavior disorder; (2) long-term comparative safety and effectiveness of various treatment options for children 6 years of age or older with ADHD; and (3) prevalence of ADHD and rates of diagnosis and treatment for ADHD. The 2011 report concluded that high strength of evidence (SOE) supported parent behavior training and low SOE supported methylphenidate (MPH) for improving the behavior of children aged 6 years or younger. The 2011 report also concluded that there was sparse evidence at the time regarding long-term outcomes following interventions for ADHD, but that treatment for 12 to 24 months with MPH or atomoxetine appeared to be associated with improvements in symptomatic behavior. This current systematic review builds on the 2011 report and also examines evidence on the diagnosis of ADHD. This report was developed to synthesize information for clinicians, scientists, and families with children with ADHD or with children suspected to have ADHD about the accuracy of diagnostic strategies and the harms and benefits of establishing the diagnosis and treating the condition.

Although different in scope, the current report primarily builds on the foundation of the 2011 report.^4^ Key findings of that report included:

- Parent behavioral interventions show benefit for ADHD symptoms for children younger than 6 years of age (high SOE).
- MPH is efficacious and generally safe for the treatment of ADHD symptoms for children younger than 6 years (low SOE). However, the studies are of short duration (lasting days to weeks).
- Psychostimulants provide control of ADHD symptoms and are well tolerated in children 6 years and older.
- Combined medication and behavioral treatment are effective in treating ADHD plus oppositional defiant disorder symptoms, primarily in boys 7–9 years of age with primarily combined type of ADHD.
- Sparse evidence at the time regarding long-term outcomes following interventions for ADHD, but treatment for 12 to 24 months with MPH or atomoxetine appeared to be associated with improvements in symptomatic behavior.

## Scope and Key Questions

### Scope of This Review

This review focuses on the diagnosis and management of ADHD within the primary care practice setting or other settings in which care can be coordinated by primary care providers (e.g., in partnership with community-based psychologists or psychiatrists). Although treatment of ADHD in childhood and adolescence is the focus, this review also evaluates outcomes in adulthood from treatment that occurs during childhood or adolescence.

Our review updates a 2011 review that focused on the effectiveness of ADHD treatment in at-risk preschoolers, the long-term effectiveness of ADHD treatment in all ages, and the variability in ADHD prevalence, diagnosis, and treatment.^4^ The current review builds on this 2011 report and addresses important gaps in knowledge related to the diagnosis of ADHD, concerns about labeling with ADHD, and conflicting literature about the effectiveness of treatment.

#### Rationale and Context

##### DSM-5 Criteria for Diagnosis

The DSM-5 criteria are the gold standard for the diagnosis of ADHD. However, most of the previous studies were developed before the release of these criteria, which were released in 2013. Compared with the DSM-IV, the DSM-5 criteria allow some symptoms to appear prior to 12 years of age compared with 7 years of age, so more adolescents fulfill the criteria. In addition, DSM-5 permits the co-occurrence of autism spectrum disorder with the diagnosis of ADHD, whereas these disorders could not be co-diagnosed in DSM-IV. The DSM-5 criteria emphasize the life-long, chronic nature of ADHD and the need to monitor individuals over time.

##### Patient Preferences

There are differences in patient and family preferences related to both pharmacologic and nonpharmacologic treatment^18^ and potential outcomes. These treatment preferences have been shown to be associated with treatment initiation and choice. Findings from this systematic review are intended to help inform patient and family decisions based on the benefits and harms of specific treatments.

##### Other Factors

Two previous AHRQ evidence reports have addressed ADHD.^4,19^ Because of the number of studies related to ADHD, this report builds on these previous reports with specific attention to issues related to diagnosis, treatment, and management of children and adolescents. In the period since the 2011 publication of the AAP clinical practice guideline,^12^ new medication formulations have become available (e.g., MPH transdermal system and suspension, lisdexamfetamine, amphetamine sulfate tablets, and dextroamphetamine sulfate tablets), and the DSM-5 has been released, increasing clinical and decisionmaking uncertainty. A separate report on disruptive behavior disorder is nearly complete and was therefore not targeted in this systematic review. However, we do include disruptive behavior specifically related to ADHD.

##### Cost

Cost assessment was not included in this review.

### Key Questions

The specific Key Questions (KQs) addressed in this review are listed below, and Figure 1 displays the analytic framework that guided our work.

- KQ 1: For the diagnosis of ADHD:
  a. What is the comparative diagnostic accuracy of approaches that can be used in the primary care practice setting or by specialists to diagnose ADHD among individuals younger than 7 years of age?
  b. What is the comparative diagnostic accuracy of EEG, imaging, or approaches assessing executive function that can be used in the primary care practice setting or by specialists to diagnose ADHD among individuals aged 7 through 17?
  c. For both populations, how does the comparative diagnostic accuracy of these approaches vary by clinical setting, including primary care or specialty clinic, or patient subgroup, including age, sex, or other risk factors associated with ADHD?
  d. What are the adverse effects associated with being labeled correctly or incorrectly as having ADHD?
- KQ 2: What are the comparative safety and effectiveness of pharmacologic and/or nonpharmacologic treatments of ADHD in improving outcomes associated with ADHD? How do these outcomes vary by presentation (inattentive, hyperactive/impulsive, and combined) or other comorbid conditions? What is the risk of diversion of pharmacologic treatment?
- KQ 3: What are the comparative safety and effectiveness of different monitoring strategies to evaluate the effectiveness of treatment or changes in ADHD status (e.g., worsening or resolving symptoms)?

Figure 1 Analytic framework for ADHD

Figure 1. Analytic framework. This figure illustrates the population, interventions, outcomes, and adverse effects that guided the literature search and synthesis. It shows how individuals through 17 years of age without ADHD may be diagnosed and treated for ADHD, and how treatment is associated with a range of potential adverse effects and outcomes. KQ 1 evaluates the comparative accuracy of approaches used to diagnose ADHD, including how the diagnostic accuracy varies by setting, patient subgroup, or other risk factors. KQ 1 also addresses adverse effects of ADHD diagnosis. KQ 2 considers the comparative safety and effectiveness of pharmacologic and nonpharmacologic treatments for ADHD and how the outcomes vary by presentation or other comorbid conditions. KQ 2 also addresses adverse effects of ADHD treatment. KQ 3 considers the comparative safety and effectiveness of different monitoring strategies to evaluate the effectiveness of treatment or changes in ADHD status over time.

The analytic framework presented in Figure 1 illustrates the population, interventions, outcomes, and adverse effects that guided the literature search and synthesis. This figure shows how individuals through 17 years of age without ADHD may be diagnosed and treated for ADHD, and how treatment is associated with a range of potential adverse effects and outcomes.^4^ KQ 1 evaluates the comparative accuracy of approaches used to diagnose ADHD, including how the diagnostic accuracy varies by setting, patient subgroup, or other risk factors. For children younger than 7 years, we included any method available to primary care clinicians (KQ 1a). However, for children 7 through 17 years, we focused on novel approaches only because other reports have assessed the standard screening instruments used for older children. Although the studies were not restricted to primary care settings, the methods have to be ones available directly or easily upon referral to primary care clinicians based on feedback from the Technical Expert Panel and internal clinical experts. KQ 1 also addresses adverse effects of ADHD diagnosis. KQ 2 considers the comparative safety and effectiveness of pharmacologic and nonpharmacologic treatments for ADHD and how the outcomes vary by presentation or other comorbid conditions. KQ 2 also addresses adverse effects of ADHD treatment. KQ 3 considers the comparative safety and effectiveness of different monitoring strategies to evaluate the effectiveness of treatment or changes in ADHD status over time.

## Organization of This Report

The remainder of the review first presents our methods followed by an overview of the results of the updated systematic review. Each results section also describes “Findings in Relation to What Is Known” to provide appropriate context for the reader. We then synthesize the literature and provide summary tables and SOE grades for the outcomes. The discussion section offers our conclusions, summarizes our findings, and provides other information relevant to interpreting this work for clinical practice and future research. Within the discussion we also include a summary table of how this updated systematic review compares and contrast to the 2011 AHRQ report in terms of the KQs addressed, populations and outcomes of interest, and the findings of the review.

Appendix A contains the exact search strings for the literature searches. Appendix B presents the data elements abstracted from the included studies. Appendix C lists the included studies. Appendix D lists the excluded studies and the reason for exclusion. Appendix E provides a key to the primary and companion articles. Appendix F presents details on the study characteristics of included studies. Appendix G presents an overview of included studies. Appendix H presents detailed data tables for the different outcomes and comparisons of interest.

A list of acronyms and abbreviations is at the end of this report.