# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Coleen Boyle, Ph.D., M.S.Hyg.^*^
  Centers for Disease Control and Prevention
  Atlanta, GA
- Theodore Ganiats, M.D.
  University of Miami
  Miami, FL
- Laurence Greenhill, M.D.^*^
  Columbia University Medical Center
  New York, NY
- William E. Pelham, Jr., Ph.D.^*^
  Florida International University
  Miami, FL
- Erin Schoenfelder Gonzalez, Ph.D.^*^
  Seattle Children’s Hospital
  Seattle, WA
- Susanna Visser, M.S., Dr.Ph.^*^
  Centers for Disease Control and Prevention
  Atlanta, GA
- Mark Wolraich, M.D.^*^
  University of Oklahoma Health Sciences Center
  Oklahoma City, OK
- Julie Zito, Ph.D.^*^
  University of Maryland
  Baltimore, MD

* Provided input on Draft Report.