# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Barry Anton, Ph.D., A.B.P.P.
  Rainier Behavioral Health
  Tacoma, WA
- William Barbaresi, M.D., FAAP
  Boston Children’s Hospital
  Boston, MA
- Coleen Boyle, Ph.D., M.S.Hyg.
  Centers for Disease Control and Prevention
  Atlanta, GA
- Teka Dempson
  National Federation of Families for Children’s Mental Health
  Durham, NC
- Theodore Ganiats, M.D.
  University of Miami
  Miami, FL
- Laurence Greenhill, M.D.
  Columbia University Medical Center
  New York, NY
- Aaron Lopata, M.D., M.P.P.
  Health Resources and Services Administration
  Maternal and Child Health Bureau
  Rockville, MD
- Doris Lotz, M.D., M.P.H.
  Chief Medical Officer
  New Hampshire Department of Health and Human Services
  Concord, NH
- Mark Wolraich, M.D.
  University of Oklahoma Health Sciences Center
  Oklahoma City, OK