# Acknowledgments

The authors thank Naomi Davis, Ph.D., for providing clinical expertise; Megan von Isenburg, M.S.L.S., for help with the literature search and retrieval; Robyn E. Schmidt, B.A., for assistance with project coordination; and Rebecca N. Gray, D.Phil., and Liz Wing, M.A., for editorial assistance.